# Helpful Web Site Addresses

The inclusion of Web sites in this appendix is intended to assist readers in finding additional information regarding the treatment of tobacco use and dependence and does not constitute endorsement of the contents of any particular site.

Addressing Tobacco in Managed Care: www.aahp.org/atmc.htm

Agency for Healthcare Research and Quality: www.ahrq.gov (http://www.ahcpr.gov/)

American Academy of Family Physicians: www.aafp.org

American Cancer Society: www.cancer.org

American Legacy Foundation: www.americanlegacy.org

American Psychological Association: www.apa.org

National Cancer Institute: www.nci.nih.gov

National Center for Tobacco-Free Kids: www.tobaccofreekids.org

National Guideline Clearinghouse: www.guideline.gov

National Heart, Lung, and Blood Institute: www.nhlbi.nih.gov/index.htm

National Institute on Drug Abuse: www.nida.nih.gov/NIDAHome1.html

Office on Smoking and Health at the Centers for Disease Control and Prevention: www.cdc.gov/tobacco (http://www.cdc.gov/tobacco/tobacco.htm)

Office on Smoking and Health at the Centers for Disease Control and Prevention: State highlights including lists of State tobacco control contacts: www.cdc.gov/tobacco/statehi/statehi.htm

Society for Research on Nicotine and Tobacco: www.srnt.org

World Health Organization: www.who.int