# Contributors

## Guideline Panel

- Michael C. Fiore, MD, MPH
- Panel Chair
- Professor, Department of Medicine
- Director, Center for Tobacco Research and Intervention
- University of Wisconsin School of Medicine and Public Health
- Madison, Wisconsin

Dr. Fiore completed medical school at Northwestern University and his internal medicine training at Boston City Hospital. His postgraduate education included a master's degree in public health in epidemiology from Harvard University. Dr. Fiore received additional training in epidemiology as an Epidemic Intelligence Service Officer for the Centers for Disease Control and Prevention, where he completed a preventive medicine residency program. Dr. Fiore worked as a medical epidemiologist at the U.S. Office on Smoking and Health, where he contributed to a wide range of national research, educational, and policy projects to control the epidemic of tobacco-related diseases. He is Director of the Center for Tobacco Research and Intervention and a Professor of Medicine at the University of Wisconsin School of Medicine and Public Health. He served as Chair of the Agency for Healthcare Policy and Research Panel that produced the Smoking Cessation Clinical Practice Guideline No. 18 (1996) and Chair of the Public Health Service Panel that produced Treating Tobacco Use and Dependence: A Clinical Practice Guideline (2000). Dr. Fiore serves as Director (with Dr. Susan Curry) of a Robert Wood Johnson Foundation National Program, Addressing Tobacco in Health Care.

- Carlos Roberto Jaén, MD, PhD, FAAFP
- Panel Vice Chair
- Professor and Chair, Department of Family and Community Medicine
- Co-Director, Center for Research in Family Medicine and Primary Care
- University of Texas Health Science Center at San Antonio
- San Antonio, Texas

Dr. Jaén completed medical school at the State University of New York at Buffalo, and his family medicine residency and primary care research fellowship at Case Western Reserve University in Cleveland, Ohio. His graduate education included a PhD in epidemiology, with a concentration in tobacco control at Roswell Park Cancer Institute. He is Professor and Chair of the Department of Family and Communty Medicine at the University of Texas Health Science Center at San Antonio. He also is Co-Director of the American Academy of Family Physicians-funded Center for Research in Family Medicine and Primary Care. Dr. Jaén, active in primary care and public health research since 1985, has authored more than 70 publications on smoking cessation and related subjects, clinical preventive service delivery in primary care offices, and access to care by the urban poor and Hispanic populations. In 2005, he was appointed to the National Advisory Council to the Agency for Healthcare Research and Quality of the U.S. Public Health Service. He is a practicing family physician in the University of Texas Health Science Center at San Antonio and has been selected to the Best Doctors in America since 2002.

- Timothy B. Baker, PhD
- Senior Scientist
- Professor, Department of Medicine
- Associate Director, Center for Tobacco Research and Intervention
- University of Wisconsin School of Medicine and Public Health
- Madison, Wisconsin

Dr. Baker is a Professor of Medicine at the University of Wisconsin School of Medicine and Public Health. His principal research goals are to increase understanding of the motivational bases of addictive disorders and to develop and evaluate treatments for such disorders. He also is highly interested in developing and using technological advances to deliver effective treatments to ameliorate health problems such as addictive disorders and cancer. Dr. Baker is a long-serving member of the NIDA-E study section, has served as the Editor of the Journal of Abnormal Psychology, is the principal investigator of the University of Wisconsin Transdisciplinary Tobacco Use Research Center award (NIDA), and has contributed chapters to multiple Reports of the Surgeon General.

- William C. Bailey, MD, FACP, FCCP
- Director, Lung Health Center
- University of Alabama at Birmingham
- Birmingham, Alabama

Dr. Bailey graduated from Tulane University Medical School in 1965. He is a Diplomate of the American Board of Internal Medicine in both Internal Medicine and Pulmonary Disease, having received certified specialty training in these disciplines at Tulane University Medical Center and Charity Hospital of Louisiana. He has been on the faculty of the University of Alabama at Birmingham (UAB) since 1973. He has practiced medicine, taught, performed research, and been involved in administrative endeavors for his entire career. He has served on the Board of Directors of the American Thoracic Society and also has served on the Council of the National Heart, Lung, and Blood Institute. He has been a member of many editorial review boards of peer-reviewed journals and has served as a frequent scientific reviewer of both scientific articles and peer-reviewed research. He currently holds the Eminent Scholar Chair in Pulmonary Diseases and also is the Director of the UAB Lung Health Center, which is devoted to research in the prevention of lung disease.

- Neal L. Benowitz, MD
- Chief, Division of Clinical Pharmacology and Experimental Therapeutics
- University of California-San Francisco
- San Francisco, California

Dr. Benowitz is Professor of Medicine, Psychiatry, and Biopharmaceutical Sciences and Chief, Division of Clinical Pharmacology and Experimental Therapeutics, University of California, San Francisco (UCSF). He received his MD from the University of Rochester School of Medicine in 1969, and he served as a resident in internal medicine at the Bronx Municipal Hospital Center from 1969 to 1971. He then completed a postdoctoral fellowship in clinical pharmacology at UCSF and joined the faculty at UCSF in 1974. His research interests have focused primarily on the human pharmacology and toxicology of nicotine, caffeine, and other stimulant drugs. He has published more than 300 research papers. Dr. Benowitz was a scientific editor of the 1988 United States Surgeon General's Report on Smoking and Health: Nicotine Addiction, and served as a member of the NIH Pharmacology Study Section. Dr. Benowitz is a member of a number of medical societies, including the American Society for Clinical Investigation and the Association of American Physicians. He has served as President of the American Society for Clinical Pharmacology and Therapeutics and the Society for Research on Nicotine and Tobacco. He has received the Ove Ferno, Alton Ochsner, and Rawls Palmer Progress in Medicine awards and the Oscar B. Hunter Award in Therapeutics for his research on nicotine, tobacco, and health, and was the 2002 UCSF Annual Distinguished Clinical Research Lecturer. Dr. Benowitz is currently Director of the Flight Attendants Medical Research Institute Center of Excellence at UCSF, principal investigator of the Pharmacogenetics of Nicotine Addiction Research Consortium, and Program Leader of the Tobacco Control Program of the UCSF Comprehensive Cancer Center.

- Susan J. Curry, PhD
- Director, Institute for Health Research and Policy
- University of Illinois-Chicago
- Chicago, Illinois

Dr. Curry is the Director of the Institute for Health Research and Policy and Professor of Health Policy and Administration at the University of Illinois at Chicago (UIC). Prior to joining UIC in 2001, she was Professor of Health Services in the School of Public Health and Community Medicine at the University of Washington, and Director and Senior Investigator at the Center for Health Studies, Group Health Cooperative. Dr. Curry's research in tobacco includes studies of motivation to quit smoking; randomized trials of promising smoking cessation and prevention interventions; and evaluations of the use and cost-effectiveness of tobacco cessation treatments under different health insurance plans, and health care costs and utilization associated with tobacco cessation. Dr. Curry serves as Director (with Dr. Michael Fiore) of a Robert Wood Johnson Foundation National Program, Addressing Tobacco in Health Care, and heads the Helping Young Smokers Quit national initiative funded by the Robert Wood Johnson Foundation, Centers for Disease Control and Prevention, and the National Cancer Institute (NCI). She currently serves on the Board of Directors for the American Legacy Foundation and is a member of the Board of Scientific Advisors for NCI.

- Sally Faith Dorfman, MD, MSHSA
- Associate Director, Medical Affairs, Infertility
- Ferring Pharmaceuticals, Inc.
- Parsippany, New Jersey

Dr. Dorfman holds a degree in economics from Harvard College, a master's degree in health services administration, and an MD from Stanford University. She trained in reproductive health epidemiology as an Epidemic Intelligence Service Officer at the Centers for Disease Control and Prevention. She is board certified both in obstetrics and gynecology and in public health/general preventive medicine, and is an alumna of the Public Health Leadership Institute. Dr. Dorfman has consulted for state, regional, national, and international organizations, and was Commissioner of Health for Orange County, New York, from 1988 to 1994, effectively implementing New York State's then new Clean Indoor Air Act. She has published and presented extensively for professional and lay audiences, co-chaired the American Medical Women's Association (AMWA) Anti-Smoking Task Force, chaired the AMWA Reproductive Health Initiative, and is the recipient of numerous honors and awards. In addition to administrative, research, and editorial responsibilities, Dr. Dorfman remains clinically active as a gynecologist.

- Erika S. Froehlicher, PhD, RN, MA, MPH
- Professor, Department of Physiological Nursing
- Department of Epidemiology & Biostatistics
- Schools of Nursing and Medicine
- University of California San-Francisco
- San Francisco, California

Dr. Froehlicher holds degrees in nursing with a minor in business administration from the University of Washington, Seattle, and an MPH and a PhD from the University of California, Los Angeles. Her areas of research and teaching are in the primary, secondary, and tertiary prevention (rehabilitation) of cardiovascular disease. She served as Co-Chair for the Cardiac Rehabilitation Guideline 1995, and as a reviewer for the Unstable Angina and Congestive Heart Failure Federal Guideline. Her specific research focus is on behavioral interventions to promote physical activity and exercise, women's health issues, and international health. Her focus with respect to smoking is on randomized clinical trials to study the efficacy of nurse-managed smoking cessation in women with cardiovascular disease, the older American smoker, and the African-American population; as well as international initiatives in Korea, Jordan, and Japan.

- Michael G. Goldstein, MD
- Associate Director, Clinical Education and Research
- Institute for Healthcare Communication
- New Haven, Connecticut

Dr. Goldstein is board certified in internal medicine and psychiatry and currently serves as an Associate Director for Clinical Education and Research at the Institute for Healthcare Communication (IHC) in New Haven, Connecticut. The IHC is a nonprofit foundation dedicated to improving health care through enhanced clinician-patient communication. Also, he is an investigator at the Centers for Behavioral and Preventive Medicine at the Miriam Hospital in Providence, Rhode Island, and an Adjunct Professor of Psychiatry and Human Behavior at the Warren Alpert Medical School of Brown University. Dr. Goldstein's primary research interests have included developing and testing interventions to enhance the delivery of smoking cessation and other preventive care interventions in primary care settings. Dr. Goldstein has served as a member of the Task Force on Nicotine Dependence of the American Psychiatric Association (APA) and also served on the APA Nicotine Dependence Practice Guideline Panel. He has published extensively in the areas of behavioral medicine, smoking cessation, and health care communication.

- Cheryl Healton, DrPH
- President and Chief Executive Officer
- American Legacy Foundation
- Washington, DC

Following the creation of the American Legacy Foundation in 1999, Dr. Healton joined the staff as the first President and Chief Executive Officer of this groundbreaking public health nonprofit, created by the historic Master Settlement Agreement between 46 state attorneys general, five U.S. territories, and the tobacco industry. Dr. Healton was selected for this post following a nationwide search, and she has worked tirelessly to further the foundation's ambitious mission: “To build a world where young people reject tobacco and anyone can quit.” During her tenure with the Foundation, she has guided the highly acclaimed, national youth tobacco prevention counter marketing campaign, truth,^®^ which has been credited in part with reducing youth smoking prevalence to its current 28 year low.

Although her current focus is aimed at reducing the deadly toll of tobacco on Americans, Dr. Healton's long and dynamic career in the field of public health has earned her national recognition and praise. She holds a doctorate from Columbia University's School of Public Health and a master's degree in public administration at New York University for health policy and planning. She joined the American Legacy Foundation from Columbia University's Joseph L. Mailman School of Public Health in New York, where she served as Head of the Division of Socio Medical Sciences and Associate Dean for Program Development.

- Patricia Nez Henderson, MD, MPH
- Vice President
- Black Hills Center for American Indian Health
- Rapid City, South Dakota

Dr. Nez Henderson received her bachelor of science degree in biochemistry from the University of Arizona and earned her doctor of medicine and master of public health degrees from Yale University. Upon graduating from medical school, Dr. Nez Henderson joined the Black Hills Center for American Indian Health, an American Indian nonprofit health organization located in Rapid City, South Dakota, where she currently serves as Vice President. In addition, Dr. Nez Henderson is a faculty member at the University of Colorado at Denver Health Sciences Center within the American Indian and Alaska Native Programs. For the past 7 years, her research interest has focused on tobacco-related issues in American Indian communities. Her research findings have been published in peer-reviewed medical journals. Through culturally appropriate and relevant research, she plans to provide Native communities with information that can be used for health planning and policy decisionmaking.

- Richard B. Heyman, MD
- Former Chair, Committee on Substance Abuse
- American Academy of Pediatrics
- Cincinnati, Ohio

A graduate of the Columbia University College of Physicians and Surgeons, Dr. Heyman practices pediatric and adolescent medicine in Cincinnati, Ohio, and serves as an Adjunct Professor of Clinical Pediatrics at the University of Cincinnati College of Medicine. He is a consultant to several adolescent chemical dependency programs and lectures widely in the area of substance abuse. As former Chairman of the Committee on Substance Abuse of the American Academy of Pediatrics, he has played a major role in the creation of the Academy's educational programs and materials, as well as the development of policy in the area of alcohol, tobacco, and other drug abuse.

- Howard K. Koh, MD, MPH, FACP
- Harvey V. Fineberg Professor of the Practice of Public Health
- Associate Dean for Public Health Practice
- Director of the Division of Public Health Practice
- Harvard School of Public Health
- Boston, Massachusetts

Dr. Koh graduated from Yale College and Yale University School of Medicine. He completed his postgraduate training at Boston City Hospital and Massachusetts General Hospital, serving as Chief Resident in both institutions. Dr. Koh has earned board certification in four medical fields (internal medicine, hematology, medical oncology, and dermatology) as well as a master of public health degree from Boston University School of Public Health. While serving as Commissioner of Public Health for the Commonwealth of Massachusetts (1997-2003), he oversaw the nationally recognized Massachusetts Tobacco Control Program. During this time, Massachusetts ranked as one of the healthiest states in the country. Dr. Koh is principal investigator of the National Cancer Institute-funded initiative MassCONECT (Massachusetts Community Networks to Eliminate Cancer Disparities through Education, Research, and Training), a project to eliminate cancer disparities in underserved communities. He has published more than 200 scientific articles in the medical and public health literature. President Bill Clinton appointed Dr. Koh to the National Cancer Advisory Board (2000-2002). Dr. Koh also has been elected to the Institute of Medicine (IOM) of the National Academies and is a member of the IOM Roundtable on Racial and Ethnic Health Disparities.

- Thomas E. Kottke, MD, MSPH
- Senior Clinical Investigator
- HealthPartners Research Foundation
- Minneapolis, Minnesota
- Professor of Medicine
- University of Minnesota
- Consulting Cardiologist
- Regions Hospital
- St. Paul, Minnesota

Dr. Kottke is a clinical cardiologist, epidemiologist, and health services researcher whose primary interest is describing, defining, and overcoming the barriers to the delivery of clinical services for the primordial, primary, and secondary prevention of chronic diseases. He has published widely on the evidence that clinical support systems are necessary for physicians and other health care professionals to provide these services to the patients they serve. Dr. Kottke was a member of the first U.S. Preventive Services Task Force.

- Harry A. Lando, PhD
- Professor, Division of Epidemiology and Community Health
- University of Minnesota
- Minneapolis, Minesota

Dr. Lando is internationally recognized for his work in smoking cessation. He has been active in this field since 1969 and has published extensively in this area, with a total of more than 170 scientific publications. He was a scientific editor of the 1988 Report of the Surgeon General, The Health Consequences of Smoking: Nicotine Addiction and a member of the Center for Child Health Research Tobacco Consortium of the American Academy of Pediatrics. He is Deputy Regional Editor for Addiction. He has consulted actively with such government and voluntary agencies as the National Heart, Lung, and Blood Institute; the National Cancer Institute; the Centers for Disease Control and Prevention; the National Institute on Drug Abuse; the Agency for Healthcare Research and Quality; the American Cancer Society; the American Lung Association; and the World Health Organization. Dr. Lando is a past president of the Society for Research on Nicotine and Tobacco and currently chairs the SRNT Global Network Committee. He is a 2006 recipient of the University of Minnesota Award for Global Engagement; this award carries with it the title of “Distinguished International Professor.” He is serving as Vice President of the 14th World Conference on Tobacco OR Health, to be held in 2009 in Mumbai, India.

- Robert E. Mecklenburg, DDS, MPH
- Consultant, Tobacco and Public Health
- Potomac, Maryland

Dr. Mecklenburg is a Diplomate of the American Board of Dental Public Health and an Assistant Surgeon General (ret. O-8). He organized and managed dental affairs for the National Cancer Institute's (NCI) Tobacco Control Research Branch and was the Tobacco-Related Research and Development Advisor for the National Institute of Dental and Craniofacial Research's Office of Science Policy and Analysis. He chaired the National Dental Tobacco-Free Steering Committee and was Vice-Chairman of the Dentistry Against Tobacco Section/Tobacco and Oral Health Committee of the FDI World Dental Federation. He chaired the committee on noncancer oral effects of tobacco for the first Surgeon General's report on smokeless tobacco. He was the principal author of the NCI publications, Tobacco Effects in the Mouth and How to Help Your Patients Stop Using Tobacco: A Manual for the Oral Health Team. Dr. Mecklenburg has published and lectured widely in the United States and abroad about dental professionals' involvement in the creation of a tobacco-free society.

- Robin Mermelstein, PhD
- Deputy Director, Institute for Health Research and Policy
- Director, Center for Health Behavior Research
- Professor, Department of Psychology
- University of Illinois-Chicago
- Chicago, Illinois

Dr. Mermelstein is Professor of Psychology, Director of the Center for Health Behavior Research, and Deputy Director of the Institute for Health Research and Policy at the University of Illinois at Chicago. She holds a PhD in clinical and community psychology from the University of Oregon. Her research interests fall broadly in the area of tobacco use, with studies ranging from longitudinal examinations of the etiology of youth smoking and interventions for adolescents to stop smoking to cessation interventions for adult smokers. Dr. Mermelstein has been the principal investigator on several grants from the National Cancer Institute (NCI) investigating trajectories of adolescent smoking, with a focus on social and emotional contextual factors. In addition, she has been funded by the Centers for Disease Control and Prevention to examine factors related to youth smoking, and by the National Heart, Lung, and Blood Institute and NCI for studies of adult smoking cessation. Dr. Mermelstein was the Director of the Robert Wood Johnson Foundation's (RWJF) Program Office, A Partners with Tobacco Use Research Centers: A Transdisciplinary Approach to Advancing Science and Policy Studies. As part of this program, the RWJF collaborated with both NCI and the National Institute on Drug Abuse in funding the Transdisciplinary Tobacco Use Research Centers.

- Patricia Dolan Mullen, DrPH
- Professor of Health Promotion and Behavioral Sciences
- University of Texas School of Public Health
- Houston, Texas

Dr. Mullen received her graduate training at the University of California, Berkeley, School of Public Health and has extensive experience in managed care. Her tobacco cessation research has focused on pregnant and postpartum women (non-Hispanic white, African American, and Hispanic) from urban and rural environments, who were both privately insured and covered by Medicaid. She also has collaborated on smoking cessation research with international populations. Dr. Mullen served on the U.S. Expert Panel for the Content of Prenatal Care and on research advisory panels on prenatal smoking cessation for the National Institutes of Health, Centers for Disease Control and Prevention, the American Cancer Society, and the Robert Wood Johnson Foundation Smoke-Free Families Program. She has conducted systematic reviews and meta-analyses of smoking cessation programs for pregnant women and other topics and served as a member and Vice-Chair of the U.S. Community Preventive Services Task Force.

- C. Tracy Orleans, PhD
- Senior Scientist and Distinguished Fellow
- Robert Wood Johnson Foundation
- Princeton, New Jersey

Dr. Orleans has led or co-led the Robert Wood Johnson Foundation (RWJF) public policy- and health care system-based grant making in the areas of tobacco control, physical activity promotion, childhood obesity prevention, and chronic disease management. She led the Foundation's Health & Behavior Team and has developed and/or managed numerous RWJF national initiatives, including Addressing Tobacco in Healthcare, Smoke-Free Families, Helping Young Smokers Quit, Bridging the Gap/Impact Teen, Substance Abuse Policy Research, Improving Chronic Illness Care, Active Living Research, and Healthy Eating Research. An internationally known clinical health psychologist, Dr. Orleans has authored or co-authored more than 200 publications; contributed to several Surgeon General's reports; served on numerous journal editorial boards, national scientific panels, and advisory groups (e.g., U.S. Preventive Services Task Force, Institute of Medicine, National Commission on Prevention Priorities); and as President of the Society of Behavioral Medicine.

- Lawrence Robinson, MD, MPH
- Deputy Health Commissioner
- Philadelphia Department of Public Health
- Health Promotion/Disease Prevention
- Philadelphia, Pennsylvania

A graduate of Harvard College, Dr. Robinson received his MD from the University of Pennsylvania School of Medicine. He received his MPH and completed a residency in preventive medicine at Johns Hopkins University. He was a resident and faculty member at Rush and Columbia University while performing his internal medicine training. As Deputy Commissioner for Health Promotion/Disease Prevention for the Philadelphia Department of Public Health, Dr. Robinson is responsible for the development, planning, implementation, and evaluation of various programs delivering medical, chronic disease prevention, and health education services. Local antitobacco projects include banning vending machines, assisting the county jail move to a smoke-free environment, Nicotrol Patch replacement, and the American Cancer Society Fresh Start Program. This train-the-trainer program was provided to the mentally ill and other targeted populations. Dr. Robinson also is a board member of the Pennsylvania American Cancer Society and Chairman of the State Tobacco Core Team. He is a member of various groups, organizations, and agencies in the community working on issues such as the State Tobacco Settlement (No Butts/Do the Right Thing) and smoking prevention for youth and specific populations, such as pregnant women.

- Maxine L. Stitzer, PhD
- Professor, Department of Psychiatry and Behavioral Sciences
- Behavioral Biology Research Center
- Johns Hopkins/Bayview Medical Center
- Baltimore, Maryland

Dr. Stitzer received her PhD in psychology and training in psychopharmacology from the University of Michigan. At Johns Hopkins University, she has developed a varied and extensive grant-supported research program focusing on both pharmacological and behavioral approaches to the treatment of substance abuse. Her many publications reflect active research interests in both illicit drug abuse and tobacco dependence. She has served as President of the Division on Psychopharmacology and Substance Abuse of the American Psychological Association, President of the Society for Research on Nicotine and Tobacco, and as a member of the Board of Directors of the College on Problems of Drug Dependence.

- Anthony C. Tommasello, PhD, MS
- Director, Office of Substance Abuse Studies
- University of Maryland School of Pharmacy
- Baltimore, Maryland

Dr. Tommasello, a pharmacist, is an Associate Professor in the Department of Pharmaceutical Health Services Research at the University of Maryland School of Pharmacy and Director, Office of Substance Abuse Studies, which he founded. He received his PhD in policy sciences from the University of Maryland, Baltimore County, and has worked in the addiction field since 1973. He is active in clinical and policy research and in addictions treatment and has created educational programs that have served as national models for pharmacists and other health and human service workers. Dr. Tommasello is President of the Maryland Pharmacists' Education and Advocacy Council, which provides advocacy and treatment referrals for impaired pharmacists. He has published in the areas of general principles of assessment and treatment, methadone maintenance care, and adolescent drug abuse and addiction and the pharmacist's role in substance abuse and addiction management.

- Louise Villejo, MPH, CHES
- Director, Patient Education Office
- Office of Public Affairs
- University of Texas M.D. Anderson Cancer Center
- Houston, Texas

As Director of the Patient Education Office at the M.D. Anderson Cancer Center, Ms. Villejo is responsible for the design, implementation, evaluation, and management of institution-wide patient and family education programs. She has designed and implemented Patient/Family Learning Centers as well as award-winning, disease-specific patient education programs, and produced more than 100 patient education print materials and videotapes. For the past 10 years, she has served on the National Cancer Institute's Advisory Boards and Patient Education Network's Steering Committee, and on numerous other Federal and private advisory and planning boards and committees. Ms. Villejo's publications include articles on cancer patient education and cultural diversity in health care.

- Mary Ellen Wewers, PhD, MPH, RN
- Professor, College of Public Health
- The Ohio State University
- Columbus, Ohio

Dr. Wewers, an Adult Nurse Practitioner, received her PhD in nursing from the University of Maryland and an MPH from Harvard University. She has been funded by the National Institutes of Health (NIH) to investigate reinforcement for nicotine in both human and animal models of dependence. Her current NIH-funded research examines nurse-managed tobacco cessation interventions in underserved groups. Dr. Wewers is past Chair of the Nursing Assembly of the American Thoracic Society and a past member of the Society's Board of Directors. She serves as Co-Program Leader for Cancer Control at The Ohio State University Comprehensive Cancer Center.

## Statistical Consultant

- Victor Hasselblad, PhD
- Statistical Methodologist
- Duke Clinical Research Institute
- Duke University
- Durham, North Carolina

## Project Staff

- Bruce Christiansen, PhD
- Project Director
- Center for Tobacco Research and Intervention
- University of Wisconsin School of Medicine and Public Health
- Madison, Wisconsin

- Megan Piper, PhD
- Project Scientist
- Center for Tobacco Research and Intervention
- University of Wisconsin School of Medicine and Public Health
- Madison, Wisconsin

- Doug Jorenby, PhD
- Project Scientist
- Center for Tobacco Research and Intervention
- University of Wisconsin School of Medicine and Public Health
- Madison, Wisconsin

- Wendy Theobald, PhD
- Senior Research Associate
- Center for Tobacco Research and Intervention
- University of Wisconsin School of Medicine and Public Health
- Madison, Wisconsin

- Cathlyn Leitzke, MSN, RN-C
- Senior Research Associate
- Center for Tobacco Research and Intervention
- University of Wisconsin School of Medicine and Public Health
- Madison, Wisconsin

- Michael Connell
- Project Database Administrator
- Center for Tobacco Research and Intervention
- University of Wisconsin School of Medicine and Public Health
- Madison, Wisconsin

## Project Administrative Staff

- David Fraser, Assistant Project Director
- Barb Bienborn
- Carlos Edge
- Linda Kurowski
- Marie Larson
- Margaret Sheldon
- Center for Tobacco Research and Intervention
- University of Wisconsin School of Medicine and Public Health
- Madison, Wisconsin

## Guideline Liaisons

- Ernestine W. Murray, RN, BSN, MAS, Project Officer
- Agency for Healthcare Research and Quality
- Rockville, Maryland

- Glen Bennett, MPH, CHES
- National Heart, Lung, and Blood Institute
- Bethesda, Maryland

- Stephen Heishman, PhD
- National Institute on Drug Abuse
- Rockville, Maryland

- Corinne Husten, MD, MPH*
- Now at: Partnership for Prevention
- Washington, DC
- Formerly at: Centers for Disease Control and Prevention
- Atlanta, Georgia

- Glen Morgan, PhD
- National Cancer Institute
- Bethesda, Maryland

- Christine Williams, MEd
- Agency for Healthcare Research and Quality
- Rockville, Maryland

## Guideline Consortium Sponsors

- Agency for Healthcare Research and Quality
- Rockville, Maryland

- American Legacy Foundation
- Washington, DC

- Centers for Disease Control and Prevention
- Atlanta, Georgia

- National Cancer Institute
- Bethesda, Maryland

- National Heart, Lung, and Blood Institute
- Bethesda, Maryland

- National Institute on Drug Abuse
- Rockville, Maryland

- The Robert Wood Johnson Foundation
- Princeton, New Jersey

- Center for Tobacco Research and Intervention
- University of Wisconsin School of Medicine and Public Health
- Madison, Wisconsin

## Contract Support

- The Scientific Consulting Group, Inc.
- Gaithersburg, Maryland

- Marcia Feinleib
- Project Director

- Joanne Brodsky
- Managing Editor

- Eric Doty
- Art Production Manager

## Article Reviewers

- Adrian Coon
- Scott Hagemann
- Christine Harbin
- Scott Johnson
- Erin Josen
- Andrew Kilgust
- Shriya Kothur
- Sean Ryan
- Maurice Shaw
- Center for Tobacco Research and Intervention
- University of Wisconsin School of Medicine and Public Health
- Madison, Wisconsin

## Peer Reviewers

- Karen Ahijevych, PhD, RN
- Professor and Associate Dean for Academic Affairs
- The Ohio State University
- Columbus, Ohio

- Jasjit Ahluwalia, MD, MPH, MS
- Executive Director, Office of Clinical Research
- University of Minnesota Academic Health Center
- Minneapolis, Minnesota

- Debra Annand, BSPH
- Project Director
- American Lung Association of DC
- Representing: DC Tobacco-Free Families Campaign
- Washington, DC

- Linda Bailey, JD, MHS
- President and Chief Executive Officer
- Representing: North American Quitline Consortium
- Phoenix, Arizona

- Dianne Barker, MHS
- President and Chief Executive Officer
- Barker Bi-Coastal Health Consultants
- Los Angeles, California

- Bruce Bender, PhD
- Professor, National Jewish Medicaland Research Center
- Representing: American Thoracic Society
- New York, New York

- Georges G. Benjamin, MD, FACP, FACEP(E)
- Executive Director
- Representing: American Public Health Association
- Washington, DC

- Stella Bialous, DrPH, RN, MScN
- President, Tobacco Policy International
- Representing: Tobacco Free Nurses
- San Francisco, California

- Alan Blum, MD, FAAFP
- Director
- University of Alabama Center for the Study of Tobacco and Society
- Tuscaloosa, Alabama

- Thomas Brandon, PhD
- Professor and Director, Tobacco Research
- Moffitt Cancer Center & Research Institute
- University of South Florida
- Tampa, Florida

- David M. Burns, MD
- Professor
- University of California-San Diego
- San Diego, California

- Michael Caldwell, MD, MPH
- Commissioner of Health
- Dutchess County Department of Health, New York
- Representing: National Association of County and City Health Officials
- Washington, DC

- Doug Campos-Outcalt, MD, MPA
- President, Arizona Academy of Family Physicians
- University of Arizona
- Representing: American Academy of Family Physicians
- Leawood, Kansas

- Matthew Carpenter, PhD
- Assistant Professor
- Medical University of South Carolina
- Representing: American College of Chest Physicians
- Northbrook, Illinois

- Sally Carter, MSW, LSW
- Director of Planning and Cessation Services Oklahoma State Department of Health
- Oklahoma City, Oklahoma

- Moon Chen, Jr., PhD, MPH
- Associate Director for Cancer Prevention and Control
- UC-Davis Cancer Center
- Representing: Asian American Network for Cancer Awareness, Research, and Treatment
- Sacramento, California

- Paul Cinciripini, PhD
- Professor
- University of Texas M.D. Anderson Cancer Center
- Houston, Texas

- Nathaniel Cobb, MD
- Chief, Chronic Disease Branch, Indian Health Service (IHS)
- Representing: Indian Health Service
- Albuquerque, New Mexico

- K. Michael Cummings, MD, PhD
- Chairman, Department of Health Behavior
- Roswell Park Cancer Institute
- Buffalo, New York

- Ronald Davis, MD
- President, American Medical Association
- Director, Center for Health Promotion & Disease Prevention
- Henry Ford Health System
- Detroit, Michigan

- Harriet De Wit, PhD
- Professor
- University of Chicago
- Chicago, Illinois

- Jacob Delarosa, MD
- Chief, Cardiothoracic Surgery
- Idaho State University
- Pocatello, Idaho

- Carlo C. DiClemente, PhD
- Lipitz Professor
- University of Maryland Baltimore Campus
- Baltimore, Maryland

- Norman Edelman, MD
- Chief Medical Officer
- Stony Brook University
- Representing: American Lung Association
- New York, New York

- Marilyn W. Edmunds, PhD, NP
- President, Nurse Practitioner Alternatives, Inc.
- Representing: American College of Nurse Practitioners
- Arlington, Virginia

- Michael Eriksen, ScD
- Professor and Director, Institute of Public Health
- Georgia State University
- Atlanta, Georgia

- Linda Hyder Ferry, MD, MPH
- Associate Professor
- Loma Linda University School of Public Health
- Representing: American College of Preventive Medicine
- Washington, DC

- Jacquelyn Fried, RDH, MS
- Associate Professor and Director
- University of Maryland Dental School
- Baltimore, Maryland

- Thomas Frieden, MD, MPH
- Commissioner, Department of Health and Mental Hygiene
- New York, New York

- Joseph Giaimo, DO, FCCP, FACOI
- Representing: American Osteopathic Association
- Chicago, Illinois

- Sam Giordano, MBA, RRT, FAARC
- Executive Director and Chief Executive Officer
- Representing: American Association for Respiratory Care
- Irving, Texas

- Thomas Glynn, PhD
- Director, Cancer Science and Trends
- Director, International Cancer Control
- Representing: American Cancer Society
- Washington, DC

- Neil E. Grunberg, PhD
- Professor
- Uniformed Services University of the Health Sciences
- Bethesda, Maryland

- Sharon Hall, PhD
- Professor in Residence
- University of California-San Francisco
- San Francisco, California

- Helen Ann Halpin, ScM, PhD
- Professor
- University of California-Berkeley
- Berkeley, California

- Kim Hamlett-Berry, PhD
- Director, Public Health National Prevention Program
- Representing: Department of Veterans Affairs
- Washington, DC

- Dorothy K. Hatsukami, PhD
- Director, Transdisciplinary Tobacco Use Research Center
- University of Minnesota Cancer Center
- Minneapolis, Minnesota

- Jack Hollis, PhD
- Senior Investigator
- Kaiser Permanente Colorado
- Denver, Colorado

- Kimberly Horn, EdD, MSW
- Robert C. Byrd Associate Professor of Community Medicine
- Associate Director of Population Health
- Mary Babb Randolph Cancer Center
- West Virginia University
- Morgantown, West Virginia

- Thomas Houston, MD
- Director, OhioHealth Nicotine Dependence Program
- Columbus, Ohio

- John Hughes, MD
- Professor
- University of Vermont
- Burlington, Vermont

- Richard D. Hurt, MD
- Director, Nicotine Dependence Center
- Mayo Clinic
- Rochester, Minnesota

- Paul Jarris, MD, MBA
- Executive Director
- Representing: Association of State and Territorial Health Officials
- Arlington, Virginia

- Martin Jarvis, DSc
- Professor Emeritus
- Department of Epidemiology and Public Health
- University College London
- London, England

- Peter Kaufmann, PhD
- Leader, Behavioral Medicine and Prevention Scientific Research Group
- National Heart, Lung, and Blood Institute
- Representing: The Society of Behavioral Medicine
- Milwaukee, Wisconsin

- Jonathan D. Klein, MD, MPH
- Acting Chief, Adolescent Medicine Division
- Department of Pediatrics
- AAP Julius B. Richmond Center of Excellence for Children
- University of Rochester
- Representing: American Academy of Pediatrics
- Elk Grove Village, Illinois

- Robert C. Klesges, PhD
- Professor
- University of Tennessee Health Science Center
- St. Jude Children's Research Hospital
- Memphis, Tennessee

- Connie Kohler, DrPH
- Associate Professor
- University of Alabama-Birmingham
- Birmingham, Alabama

- B. Waine Kong, PhD, JD
- Chief Executive Officer
- Representing: Association of Black Cardiologists
- Atlanta, Georgia

- Elizabeth Kraft, MD, MHS
- Medical Director, Provider Education and Resource Tobacco Program
- Representing: Colorado Clinical Guidelines Collaborative
- Lakewood, Colorado

- Jerry A. Krishnan, MD, PhD
- Associate Professor
- University of Chicago Medical Center
- Representing: American Heart Association
- Dallas, Texas

- Scott Leischow, PhD
- Professor
- University of Arizona
- Tucson, Arizona

- Caryn Lerman, PhD
- Mary W. Calkins Professor
- University of Pennsylvania School of Medicine
- Philadelphia, Pennsylvania

- Sandra Zelman Lewis, PhD
- Assistant Vice President, Health and Science Policy/Quality American College of Chest Physicians
- Northbrook, Illinois

- Edward Lichtenstein, PhD
- Senior Scientist
- Oregon Research Institute
- Eugene, Oregon

- Henri R. Manasse, Jr., PhD, ScD, RPH
- Executive Vice President and Chief Executive Officer
- Representing: American Society of Health-System Pharmacists
- Bethesda, Maryland

- Marc Manley, MD, MPH
- Vice President and Medical Director
- BlueCross BlueShield of Minnesota
- St. Paul, Minnesota

- James R. Marshall, PhD
- Senior Vice President and Chair, Department of Cancer Prevention and Population Sciences
- Roswell Park Cancer Institute
- Representing: American Society of Preventive Oncology
- Madison, Wisconsin

- Patrick E. McBride, MD, MPH
- Professor
- Co-Director, Preventative Cardiology Program
- University of Wisconsin School of Medicine and Public Health
- Madison, Wisconsin

- Robert K. McLellan, MD, MPH, FACOEM, FAAFP
- Medical Director, Dartmouth-Hitchcock Medical Center Employee Health System
- Representing: American College of Occupational and Environmental Medicine
- Elk Grove Village, Illinois

- Cathy Melvin, PhD, MPH
- Faculty Director, Lineberger Comprehensive Cancer Center
- University of North Carolina-Chapel Hill
- Representing: Smokefree Families National Partnership
- Chapel Hill, North Carolina

- Norman Montalto, DO, FAAFP
- Medical Director
- Wells Fargo TPA
- West Virginia University
- Morgantown, West Virginia

- Claudia Morrissey, MD, MPH
- President Elect
- Representing: American Medical Women's Association
- Philadelphia, Pennsylvania

- Mildred Morse, JD, CTAS
- President, Morse Enterprises
- National Tobacco Independence Campaign
- Washington, DC

- Myra Muramoto, MD, MPH
- Associate Professor
- Family and Community Medicine, Public Health
- University of Arizona Colleges of Medicine & Public Health
- Tucson, Arizona

- Matthew L. Myers, JD
- President and Chief Executive Officer
- Representing: Campaign for Tobacco-Free Kids
- Washington, DC

- Raymond Niaura, PhD
- Professor
- Warren Alpert Medical School of Brown University
- Representing: Society for Research on Nicotine and Tobacco
- Madison, Wisconsin

- Lloyd F. Novick, MD, MPH
- President
- Representing: Association for Prevention Teaching and Research
- Washington, DC

- Judy Ockene, PhD, MEd
- Professor
- University of Massachusetts Medical School
- Worcester, Massachusetts

- Stephanie O'Malley, PhD
- Professor
- Yale University School of Medicine
- New Haven, Connecticut

- Deborah Ossip-Klein, PhD
- Director, Smoking Research Program
- University of Rochester Medical Center
- Rochester, New York

- Kenneth Perkins, PhD
- Professor
- University of Pittsburgh
- Pittsburgh, Pennsylvania

- Allan Prochazka, MD, MSc
- Assistant Chief
- Denver VA Medical Center
- Representing: Society of General Internal Medicine
- Washington, DC

- Kathleen Rankin, DDS
- Baylor College of Dentistry
- Texas A&M University Health System Science Center
- Representing: American Dental Association
- Chicago, Illinois

- Bob Rehm, MBA
- Vice President, Public Health and Clinical Strategies
- Representing: America's Health Insurance Plans
- Washington, DC

- Stephen Rennard, MD
- Larson Professor
- University of Nebraska Medical Center
- Omaha, Nebraska

- Robert Richards, MA, CADCIII, NCACII
- NAADAC Northwest Regional Vice President
- Representing: The Association for Addiction Professionals
- Alexandria, Virginia

- Nancy Rigotti, MD
- Professor of Medicine, Harvard Medical School
- Representing: American College of Physicians
- Philadelphia, Pennsylvania

- Diane Roberts, DrPH
- Associate Professor
- Indiana University East
- Richmond, Indiana

- Gennette Robinson, RDH, MS
- Immediate Past President
- Representing: National Dental Hygienists' Association
- Chicago, Illinois

- Patricia A. Rowell, PhD, RN, CNP
- Representing: American Nurses Association
- Silver Spring, Maryland

- Linda Sarna, DNSc, RN, FAAN
- Associate Professor
- University of California-Los Angeles School of Nursing
- Representing: TobaccoFree Nurses
- San Francisco, California

- Steve A. Schroeder, MD
- Distinguished Professor of Health and Health Care, Department of Medicine
- Director, Smoking Cessation
- University of California-San Francisco
- San Francisco, California

- Herbert Severson, PhD
- Senior Research Scientist
- Oregon Research Institute
- Eugene, Oregon

- Gerard A. Silvestri, MD, MS, FCCP
- Professor
- Medical University of South Carolina
- Representing: American College of Chest Physicians
- Northbrook, Illinois

- Carol Southard, RN, MSN
- Smoking Cessation Specialist
- Northwest Memorial Hospital
- Representing: American Dental Hygienist Association
- Chicago, Illinois

- Bonnie Spring, PhD, ABPP
- Professor
- Northwestern University
- Representing: The Society of Behavioral Medicine
- Milwaukee, Wisconsin

- Lindsay Stead, MA, MSc
- Review Coordinator
- Cochrane Tobacco Addiction Group
- University of Oxford
- Headington, Oxford

- Jan Stine, BSEd
- Tobacco Program Consultant
- Ohio Department of Health
- Columbus, Ohio

- Steven Sussman, PhD
- Professor
- University of Southern California
- Los Angeles, California

- Amber Hardy Thornton, MPH, CHES
- Executive Vice President for Program Development
- American Legacy Foundation
- Washington, DC

- Olga Tompkins, MPH, RN, COHN-S/SM, FAAOHN
- Representing: American Association of Occupational Health Nurses
- Atlanta, Georgia

- Richard W. Valachovic, DMD, MPH
- Executive Director
- Representing: American Dental Education Association

- Rudy Valenzuela, FSP, MSN, RN, FNP-C
- President and Chief Executive Officer, FSP Health Ministries
- Representing: National Association of Hispanic Nurses
- Washington, DC

- Frank Vitale, MA
- Senior Lecturer, Pharmaceutical Sciences
- University of Pittsburgh
- Representing: Pharmacy Partnership for Tobacco Cessation
- Bethesda, Maryland

- Kenneth E. Warner, PhD
- Director
- University of Michigan Tobacco Research Network
- Ann Arbor, Michigan

- Larry N. Williams, DDS, MAGD
- Captain, Dental Corps
- U.S. Navy
- Great Lakes, Illinois

- David Willoughby, MA
- Chief Executive Officer
- Clearway Minnesota
- Minneapolis, Minnesota

- Richard Windsor, PhD, MS, MPH
- Professor
- George Washington University
- School of Public Health and Health Services
- Washington, DC

- Richard A. Yoast, PhD
- Director, Reducing Underage Drinking Through Coalitions
- American Medical Association
- Chicago, Illinois

- Kathy Zaiken, PharmD
- Assistant Professor
- Massachusetts College of Pharmacy and Health Sciences
- Representing: American Association of Colleges of Pharmacy
- Alexandria, Virginia