# Acknowledgments

This Guideline would not have been possible without the collaborative efforts of many individuals and organizations. Each made significant contributions throughout the process of updating this document. Although too numerous to list here, the Contributors section of this publication provides a listing of support staff, individual peer reviewers, and others. Some individuals and organizations, however, deserve special mention.

The Panel wishes to acknowledge the support and guidance provided by the consortium partners in general and their dedicated, hard-working representatives in particular. In addition to the Guideline Liaisons, the Panel gratefully acknowledges the extraordinarily supportive efforts and substantial contributions of Jean Slutsky, Director, Center for Outcomes and Evidence, AHRQ, and the staff at the Office of Communications and Knowledge Transfer, AHRQ; Sandra Cummings, Deputy Director of Operations, Publishing Team; Harriett Bennett, Public Affairs and Marketing Specialist; and Julius Patterson, Guideline Managing Editor.

The Panel also wishes to thank Victor Hasselblad, PhD, who served the project as statistical consultant.