# Guideline Update Development and Use

The 2008 update to Treating Tobacco Use and Dependence, a Public Health Service-sponsored Clinical Practice Guideline, is the result of an extraordinary partnership among Federal Government and nonprofit organizations comprised of the Agency for Healthcare Research and Quality; Centers for Disease Control and Prevention; National Cancer Institute; National Heart, Lung, and Blood Institute; National Institute on Drug Abuse; Robert Wood Johnson Foundation; American Legacy Foundation; and University of Wisconsin School of Medicine and Public Health's Center for Tobacco Research and Intervention. Each member of this consortium is dedicated to improving the Nation's public health, and their participation in this collaboration clearly demonstrates a strong commitment to tobacco cessation.

This Guideline is an updated version of the 2000 Treating Tobacco Use and Dependence Guideline. It is the product of a private-sector panel of experts (“the Panel”), consortium representatives, and staff. The update was written to include new, effective clinical treatments for tobacco dependence that have become available since the 2000 Guideline was published. Treating Tobacco Use and Dependence: 2008 Update will make an important contribution to the quality of care in the United States and the health of the American people.

The Panel employed an explicit, science-based methodology and expert clinical judgment to develop recommendations on the treatment of tobacco use and dependence. Extensive literature searches were conducted, and critical reviews and syntheses were used to evaluate empirical evidence and significant outcomes. Peer reviews were undertaken and public comment invited to evaluate the validity, reliability, and utility of the Guideline for clinical practice. The Panel's recommendations primarily are based on published, evidence-based research. When the evidence was incomplete or inconsistent in a particular area, the recommendations reflect the professional judgment of Panel members.

The recommendations herein may not be appropriate for use in all circumstances and are designed particularly for clinical settings. Decisions to adopt any particular recommendation must be made by clinicians in light of available resources and circumstances presented by individual patients and in light of new clinical information such as that provided by the U.S. Food and Drug Administration (FDA).

This Public Health Service-sponsored Clinical Practice Guideline update gives hope to the 7 out of 10 smokers who visit a clinician each year. This Guideline urges every clinician, health plan, and health care institution to make treating tobacco dependence a top priority during these visits. Please ask your patients two key questions: “Do you smoke?” and “Do you want to quit?” followed by use of the recommendations in this Guideline.