# Guideline Panel

Michael C. Fiore, MD, MPH (Panel Chair)

Carlos Roberto Jaén, MD, PhD, FAAFP (Panel Vice Chair)

Timothy B. Baker, PhD (Senior Scientist)

William C. Bailey, MD, FACP, FCCP

Neal L. Benowitz, MD

Susan J. Curry, PhD

Sally Faith Dorfman, MD, MSHSA

Erika S. Froelicher, PhD, RN, MA, MPH

Michael G. Goldstein, MD

Cheryl G. Healton, DrPH

Patricia Nez Henderson, MD, MPH

Richard B. Heyman, MD

Howard K. Koh, MD, MPH, FACP

Thomas E. Kottke, MD, MSPH

Harry A. Lando, PhD

Robert E. Mecklenburg, DDS, MPH

Robin J. Mermelstein, PhD

Patricia Dolan Mullen, DrPH

C. Tracy Orleans, PhD

Lawrence Robinson, MD, MPH

Maxine L. Stitzer, PhD

Anthony C. Tommasello, PhD, MS

Louise Villejo, MPH, CHES

Mary Ellen Wewers, PhD, MPH, RN

Guideline Liaisons

Ernestine W. Murray, RN, BSN, MAS, (Project Officer), Agency for Healthcare Research and Quality

Glenn Bennett, MPH, CHES, National Heart, Lung, and Blood Institute

Stephen Heishman, PhD, National Institute on Drug Abuse

Corinne Husten, MD, MPH, Centers for Disease Control and Prevention

Glen Morgan, PhD, National Cancer Institute

Christine Williams, MEd, Agency for Healthcare Research and Quality

Guideline Staff

Bruce A. Christiansen, PhD (Project Director)

Megan E. Piper, PhD (Project Scientist)

Victor Hasselblad, PhD (Project Statistician)

David Fraser, MS (Project Coordinator)

Wendy Theobald, PhD (Editorial Associate)

Michael Connell, BS (Database Manager)

Cathlyn Leitzke, MSN, RN-C (Project Researcher)

U.S. Department of Health and Human Services

Public Health Service