# Clinical Interventions for Tobacco Use and Dependence

## Background

This section of the Guideline presents specific strategies to guide clinicians providing brief interventions (less than 10 minutes). These brief interventions can be provided by all clinicians but are most relevant to clinicians who see a wide variety of patients and are bound by time constraints (e.g., physicians, nurses, physician assistants, nurse practitioners, medical assistants, dentists, hygienists, respiratory therapists, mental health counselors, pharmacists, etc.). The strategies in this chapter are based on the evidence described in Chapters 6 and 7, as well as on Panel opinion. Guideline analysis suggests that a wide variety of clinicians can implement these strategies effectively.

Why should members of a busy clinical team consider making the treatment of tobacco use a priority? The evidence is compelling: (1) clinicians can make a difference with even a minimal (less than 3 minutes) intervention (see Chapter 6); (2) a relation exists between the intensity of intervention and tobacco cessation outcome (see Chapter 6); (3) even when patients are not willing to make a quit attempt at this time, clinician-delivered brief interventions enhance motivation and increase the likelihood of future quit attempts^122^ (see Chapter 6); (4) tobacco users are being primed to consider quitting by a wide range of societal and environmental factors (e.g., public health messages, policy changes, cessation marketing messages, family members); (5) there is growing evidence that smokers who receive clinician advice and assistance with quitting report greater satisfaction with their health care than those who do not;^23,^,^87,88^ (6) tobacco use interventions are highly cost effective (see Chapter 6); and (7) tobacco use has a high case fatality rate (up to 50% of long-term smokers will die of a smoking-caused disease^123^).

The goal of these strategies is clear: to change clinical culture and practice patterns to ensure that every patient who uses tobacco is identified, advised to quit, and offered scientifically sound treatments. The strategies underscore a central theme: it is essential to provide at least a brief intervention to every tobacco user at each health care visit. Responsibility lies with both the clinician and the health care system to ensure that this occurs. Several observations are relevant to this theme. First, although many smokers are reluctant to seek intensive treatments,^124,125^ they nevertheless can receive a brief intervention every time they visit a clinician.^66,126^ Second, institutional support is necessary to ensure that all patients who use tobacco are identified and offered appropriate treatment (see Chapter 5, Systems Interventions: Importance to Health Care Administrators, Insurers, and Purchasers). Third, the time limits on primary care physicians in the United States today (median visit = 12–16 minutes),^127,128^ as well as reimbursement restrictions, often limit providers to brief interventions, although more intensive interventions would produce greater success. Finally, given the growing use of electronic patient databases, smoker registries, and real-time clinical care prompts, brief interventions may be easier to fit into a busy practice and may be implemented in a variety of ways.

This chapter is divided into three sections to guide brief clinician interventions with three types of patients: (A) current tobacco users willing to make a quit attempt at this time; (B) current tobacco users unwilling to make a quit attempt at this time; and (C) former tobacco users who have recently quit. Patients who have never used tobacco or who have been abstinent for an extended period should be congratulated on their status and encouraged to maintain their tobacco-free lifestyle.

Given that more than 70 percent of tobacco users visit a physician and more than 50 percent visit a dentist each year,^129^ it is essential that these clinicians be prepared to intervene with all tobacco users. The five major components (the “5 A's”) of a brief intervention in the primary care setting are listed in Table 3.1. It is important for a clinician to ask the patient if he or she uses tobacco (Strategy A1), advise him or her to quit (Strategy A2), and assess willingness to make a quit attempt (Strategy A3). Strategies A1 to A3 need to be delivered to each tobacco user, regardless of his or her willingness to quit.

Table 3.1 The “5 A's” model for treating tobacco use and dependence

Ask about tobacco use. | Identify and document tobacco use status for every patient at every visit. (Strategy A1)
Advise to quit. | In a clear, strong, and personalized manner, urge every tobacco user to quit. (Strategy A2)
Assess willingness to make a quit attempt. | Is the tobacco user willing to make a quit attempt at this time? (Strategy A3)
Assist in quit attempt. | For the patient willing to make a quit attempt, offer medication and provide or refer for counseling or additional treatment to help the patient quit. (Strategy A4) For patients unwilling to quit at the time, provide interventions designed to increase future quit attempts. (Strategies B1 and B2)
Arrange followup. | For the patient willing to make a quit attempt, arrange for followup contacts, beginning within the first week after the quit date. (Strategy A5) For patients unwilling to make a quit attempt at the time, address tobacco dependence and willingness to quit at next clinic visit.

If the patient is willing to quit, the clinician should assist him or her in making a quit attempt by offering medication and providing or referring for counseling or additional treatment (Strategy A4), and arrange for followup contacts to prevent relapse (Strategy A5). If the patient is unwilling to make a quit attempt, the clinician should provide a motivational intervention (Strategies B1 and B2) and arrange to address tobacco dependence at the next clinic visit. The Strategy tables below (A1–A5) comprise suggestions for the content and delivery of the 5 A's. The strategies are designed to be brief and require 3 minutes or less of direct clinician time. These intervention components constitute the core elements of a tobacco intervention, but they need not be applied in a rigid, invariant manner. For instance, the clinician need not deliver all elements personally. One clinician (e.g., a medical assistant) may ask about tobacco use status; and a prescribing clinician (e.g., physician, dentist, physician assistant, nurse practitioner) may deliver personal advice to quit, assess willingness to quit, and assist with medications, but then refer the patient to a tobacco intervention resource (e.g., a tobacco cessation quitline, health educator) that would deliver additional treatment to the patient. The clinician would remain responsible for the patient receiving appropriate care and subsequent followup, but, as with other sorts of health care, an individual clinician would not need to deliver all care personally.^130^ Evidence indicates that full implementation of the 5 A's in clinical settings may yield results that are superior to partial implementation.^131^

The effectiveness of tobacco intervention may reflect not only the contributions of the individual clinician, but also the systems and other clinical resources available to him or her. For instance, office systems that institutionalize tobacco use assessment and intervention will greatly foster the likelihood that the 5 A's will be delivered (see Chapter 5). The 5 A's, as described in Table 3.1, are consistent with those recommended by the NCI^132,133^ and the American Medical Association,^77^ as well as others.^75,134^–^137^ The clinical situation may suggest delivering these intervention components in an order or format different from that presented, however. For example, clinical interventions such as: Ask/Assess, Advise, Agree on a goal, Assist, Arrange followup; Ask and Act; and Ask, Advise, and Refer have been proposed.^116,^,^130,138^–^140^

When “Assisting” smokers, in addition to counseling, all smokers making a quit attempt should be offered medication, except when contraindicated or with specific populations for which there is insufficient evidence of effectiveness (i.e., pregnant women, smokeless tobacco users, light smokers, and adolescents). See Tables 3.2 to 3.11 for guidelines for prescribing medication for treating tobacco use and dependence.

Table 3.2 Clinical guidelines for prescribing medication for treating tobacco use and dependence

Who should receive medication for tobacco use? Are there groups of smokers for whom medication has not been shown to be effective? | All smokers trying to quit should be offered medication, except when contraindicated or for specific populations for which there is insufficient evidence of effectiveness (i.e., pregnant women, smokeless tobacco users, light smokers, and adolescents; see Chapter 7).
What are the first-line medications recommended in this Guideline update? | All seven of the FDA-approved medications for treating tobacco use are recommended: bupropion SR, nicotine gum, nicotine inhaler, nicotine lozenge, nicotine nasal spray, nicotine patch, and varenicline. The clinician should consider the first-line medications shown to be more effective than the nicotine patch alone: 2 mg/day varenicline or the combination of long-term nicotine patch use + ad libitum nicotine replacement therapy (NRT). Unfortunately, there are no well-accepted algorithms to guide optimal selection among the first-line medications.
Are there contraindications, warnings, precautions, other concerns, and side effects regarding the first-line medications recommended in this Guideline update? | All seven FDA-approved medications have specific contraindications, warnings, precautions, other concerns, and side effects. Refer to FDA package inserts for this complete information and FDA updates to the individual drug tables in this document (Tables 3.3–3.9). (See information below regarding second-line medications.)
What other factors may influence medication selection? | Pragmatic factors also may influence selection, such as insurance coverage, out-of-pocket patient costs, likelihood of adherence, dentures when considering the gum, or dermatitis when considering the patch.
Is a patient's prior experience with a medication relevant? | Prior successful experience (sustained abstinence with the medication) suggests that the medication may be helpful to the patient in a subsequent quit attempt, especially if the patient found the medication to be tolerable and/or easy to use. However, it is difficult to draw firm conclusions from prior failure with a medication. Some evidence suggests that re-treating relapsed smokers with the same medication produces small or no benefit,^142,143^ whereas other evidence suggests that it may be of substantial benefit.^144^
What medications should a clinician use with a patient who is highly nicotine dependent? | The higher-dose preparations of nicotine gum, patch, and lozenge have been shown to be effective in highly dependent smokers.^145^–^147^ Also, there is evidence that combination NRT therapy may be particularly effective in suppressing tobacco withdrawal symptoms.^148,149^ Thus, it may be that NRT combinations are especially helpful for highly dependent smokers or those with a history of severe withdrawal.
Is gender a consideration in selecting a medication? | There is evidence that NRT can be effective with both sexes;^150^–^152^ however, evidence is mixed as to whether NRT is less effective in women than men.^153^–^157^ This may encourage the clinician to consider use of another type of medication with women, such as bupropion SR or varenicline.
Are cessation medications appropriate for light smokers (i.e., < 10 cigarettes/day)? | As noted above, cessation medications have not been shown to be beneficial to light smokers. However, if NRT is used with light smokers, clinicians may consider reducing the dose of the medication. No adjustments are necessary when using bupropion SR or varenicline.
When should second-line agents be used for treating tobacco dependence? | Consider prescribing second-line agents (clonidine and nortriptyline) for patients unable to use first-line medications because of contraindications or for patients for whom the group of first-line medications has not been helpful. Assess patients for the specific contraindications, precautions, other concerns, and side effects of the second-line agents. Refer to FDA package inserts for this information and to the individual drug tables in this document (Tables 3.10 and 3.11).
Which medications should be considered with patients particularly concerned about weight gain? | Data show that bupropion SR and nicotine replacement therapies, in particular 4-mg nicotine gum and 4-mg nicotine lozenge, delay—but do not prevent—weight gain.
Are there medications that should especially be considered for patients with a past history of depression? | Bupropion SR and nortriptyline appear to be effective with this population^158^–^162^ (see Chapter 7), but nicotine replacement medications also appear to help individuals with a past history of depression.
Should nicotine replacement therapies be avoided in patients with a history of cardiovascular disease? | No. The nicotine patch in particular has been demonstrated as safe for cardiovascular patients. See Tables 3.3–3.9 and FDA package inserts for more complete information.
May tobacco dependence medications be used long-term (e.g., up to 6 months)? | Yes. This approach may be helpful with smokers who report persistent withdrawal symptoms during the course of medications, who have relapsed in the past after stopping medication, or who desire long-term therapy. A minority of individuals who successfully quit smoking use ad libitum NRT medications (gum, nasal spray, inhaler) long-term. The use of these medications for up to 6 months does not present a known health risk, and developing dependence on medications is uncommon. Additionally, the FDA has approved the use of bupropion SR, varenicline, and some NRT medications for 6-month use.
Is medication adherence important? | Yes. Patients frequently do not use cessation medications as recommended (e.g., they do not use them at recommended doses or for recommended durations); this may reduce their effectiveness.
May medications ever be combined? | Yes. Among first-line medications, evidence exists that combining the nicotine patch long-term ( > 14 weeks) with either nicotine gum or nicotine nasal spray, the nicotine patch with the nicotine inhaler, or the nicotine patch with bupropion SR, increases long-term abstinence rates relative to placebo treatments. Combining varenicline with NRT agents has been associated with higher rates of side effects (e.g., nausea, headaches).

Table 3.11 Clinical use of nortriptyline (See FDA package insert for more complete information.)

| Clinical use of nortriptyline (not FDA approved for smoking cessation)
Patient selection | Appropriate as a second-line medication for treating tobacco use
Precautions, warnings, contraindications, and side effects (see FDA package insert for complete list) | Pregnancy - Pregnant smokers should be encouraged to quit without medication. Nortriptyline has not been shown to be effective for tobacco cessation in pregnant smokers. (Nortriptyline is an FDA pregnancy Class D agent.) Nortriptyline has not been evaluated in breastfeeding patients. Side effects - Most commonly reported side effects include sedation, dry mouth (64–78%), blurred vision (16%), urinary retention, lightheadedness (49%), and shaky hands (23%). Activities - Nortriptyline may impair the mental and/or physical abilities required for the performance of hazardous tasks, such as operating machinery or driving a car; therefore, the patient should be warned accordingly. Cardiovascular and other effects - Because of the risk of arrhythmias and impairment of myocardial contractility, use with caution in patients with cardiovascular disease. Do not co-administer with MAO inhibitors.
Dosage | Doses used in smoking cessation trials have initiated treatment at a dose of 25 mg/day, increasing gradually to a target dose of 75–100 mg/day. Duration of treatment used in smoking cessation trials has been approximately 12 weeks, although clinicians may consider extending treatment for up to 6 months.
Availability | Nortriptyline HCl - prescription only
Prescribing instructions | Initiate - Therapy is initiated 10–28 days before the quit date to allow nortriptyline to reach steady state at the target dose. Therapeutic monitoring - Although therapeutic blood levels for smoking cessation have not been determined, therapeutic monitoring of plasma nortriptyline levels should be considered under American Psychiatric Association Guidelines for treating patients with depression. Clinicians may choose to assess plasma nortriptyline levels as needed.^163^ Dosing information - Users should not discontinue nortriptyline abruptly because of withdrawal effects. Overdose may produce severe and life-threatening cardiovascular toxicity, as well as seizures and coma. Risk of overdose should be considered carefully before using nortriptyline.
Cost^a^ | 25 mg, box of 60 = $24 (daily dosage determines how long supply lasts)

a Cost data were established by averaging the retail price of the medication at national chain pharmacies in Atlanta, GA, Los Angeles, CA, Milwaukee, WI, Sunnyside, NY, and listed online during January 2008 and may not reflect discounts available to health plans and others.

## A. For the Patient Willing To Quit

Table A1 Strategy. Ask—Systematically identify all tobacco users at every visit

Action | Strategies for implementation
Implement an officewide system that ensures that, for every patient at every clinic visit, tobacco use status is queried and documented.^a^ | Expand the vital signs to include tobacco use, or use an alternative universal identification system.^b^ VITAL SIGNS Blood Pressure: _______________________ Pulse: ________ Weight: ___________ Temperature: _________________________ Respiratory Rate: ______________________ Tobacco Use (circle one): Current Former Never

a Repeated assessment is not necessary in the case of the adult who has never used tobacco or has not used tobacco for many years and for whom this information is clearly documented in the medical record.

b Alternatives to expanding the vital signs include using tobacco use status stickers on all patient charts or indicating tobacco use status via electronic medical records or computerized reminder systems.

Table A2 Strategy. Advise—Strongly urge all tobacco users to quit

Action | Strategies for implementation
In a clear, strong, and personalized manner, urge every tobacco user to quit. | Advice should be:; - Clear—“It is important that you quit smoking (or using chewing tobacco) now, and I can help you.” “Cutting down while you are ill is not enough.” “Occasional or light smoking is still dangerous.”; - Strong—“As your clinician, I need you to know that quitting smoking is the most important thing you can do to protect your health now and in the future. The clinic staff and I will help you.”; - Personalized—Tie tobacco use to current symptoms and health concerns, and/or its social and economic costs, and/or the impact of tobacco use on children and others in the household. “Continuing to smoke makes your asthma worse, and quitting may dramatically improve your health.” “Quitting smoking may reduce the number of ear infections your child has.”

Table A3 Strategy. Assess—Determine willingness to make a quit attempt

Action | Strategies for implementation
Assess every tobacco user's willingness to make a quit attempt at the time. | Assess patient's willingness to quit: “Are you willing to give quitting a try?”; - If the patient is willing to make a quit attempt at the time, provide assistance (see Chapter 3A, Strategy A4).; - If the patient will participate in an intensive treatment, deliver such a treatment or link/refer to an intensive intervention (see Chapter 4).; - If the patient is a member of a special population (e.g., adolescent, pregnant smoker, racial/ethnic minority), consider providing additional information (see Chapter 7).; - If the patient clearly states that he or she is unwilling to make a quit attempt at the time, provide an intervention shown to increase future quit attempts (see Chapter 3B).

Table A4 Strategy. Assist—Aid the patient in quitting (provide counseling and medication)

Action | Strategies for implementation
Help the patient with a quit plan. | A patient's preparations for quitting:; - Set a quit date. Ideally, the quit date should be within 2 weeks.; - Tell family, friends, and coworkers about quitting, and request understanding and support.; - Anticipate challenges to the upcoming quit attempt, particularly during the critical first few weeks. These include nicotine withdrawal symptoms.; - Remove tobacco products from your environment. Prior to quitting, avoid smoking in places where you spend a lot of time (e.g., work, home, car). Make your home smoke-free.
Recommend the use of approved medication, except when contraindicated or with specific populations for which there is insufficient evidence of effectiveness (i.e., pregnant women, smokeless tobacco users, light smokers, and adolescents). | Recommend the use of medications found to be effective in this Guideline (see Table 3.2 for clinical guidelines and Tables 3.3–3.11 for specific instructions and precautions). Explain how these medications increase quitting success and reduce withdrawal symptoms. The first-line medications include: bupropion SR, nicotine gum, nicotine inhaler, nicotine lozenge, nicotine nasal spray, nicotine patch, and varenicline; second-line medications include: clonidine and nortriptyline. There is insufficient evidence to recommend medications for certain populations (e.g., pregnant women, smokeless tobacco users, light smokers, adolescents).
Provide practical counseling (problemsolving/skills training). | Abstinence. Striving for total abstinence is essential. Not even a single puff after the quit date.^141^ Past quit experience. Identify what helped and what hurt in previous quit attempts. Build on past success. Anticipate triggers or challenges in the upcoming attempt. Discuss challenges/triggers and how the patient will successfully overcome them (e.g., avoid triggers, alter routines). Alcohol. Because alcohol is associated with relapse, the patient should consider limiting/abstaining from alcohol while quitting. (Note that reducing alcohol intake could precipitate withdrawal in alcohol-dependent persons.) Other smokers in the household. Quitting is more difficult when there is another smoker in the household. Patients should encourage housemates to quit with them or to not smoke in their presence. For further description of practical counseling, see Table 6.19.
Provide intratreatment social support. | Provide a supportive clinical environment while encouraging the patient in his or her quit attempt. “My office staff and I are available to assist you.”“I'm recommending treatment that can provide ongoing support.” For further description of intratreatment social support, see Table 6.20.
Provide supplementary materials, including information on quitlines. | Sources: Federal agencies, nonprofit agencies, national quitline network (1-800-QUIT-NOW), or local/state/tribal health departments/quitlines (see Appendix B for Web site addresses). Type: Culturally/racially/educationally/age-appropriate for the patient. Location: Readily available at every clinician's workstation.
For the smoker unwilling to quit at the time | See Section 3B.

Table A5 Strategy. Arrange—Ensure followup contact

Action | Strategies for implementation
Arrange for followup contacts, either in person or via telephone. | Timing: Followup contact should begin soon after the quit date, preferably during the first week. A second followup contact is recommended within the first month. Schedule further followup contacts as indicated. Action during followup contact: For all patients, identify problems already encountered and anticipate challenges in the immediate future. Assess medication use and problems. Remind patients of quitline support (1-800-QUIT-NOW). Address tobacco use at next clinical visit (treat tobacco use as a chronic disease). For patients who are abstinent, congratulate them on their success. If tobacco use has occurred, review circumstances and elicit recommitment to total abstinence. Consider use of or link to more intensive treatment (see Chapter 4).
For smokers unwilling to quit at the time | See Section 3B.

## B. For the Patient Unwilling To Quit

### Promoting the Motivation To Quit

All patients entering a health care setting should have their tobacco use status assessed routinely. Clinicians should advise all tobacco users to quit and then assess a patient's willingness to make a quit attempt. For patients not ready to make a quit attempt at the time, clinicians should use a brief intervention designed to promote the motivation to quit.

Patients unwilling to make a quit attempt during a visit may lack information about the harmful effects of tobacco use and the benefits of quitting, may lack the required financial resources, may have fears or concerns about quitting, or may be demoralized because of previous relapse.^164^–^167^ Such patients may respond to brief motivational interventions that are based on principles of Motivational Interviewing (MI),^168^ a directive, patient-centered counseling intervention.^169^ There is evidence that MI is effective in increasing future quit attempts;^170^–^174^ however, it is unclear that MI is successful in boosting abstinence among individuals motivated to quit smoking.^173,^,^175,176^

Clinicians employing MI techniques focus on exploring a tobacco user's feelings, beliefs, ideas, and values regarding tobacco use in an effort to uncover any ambivalence about using tobacco.^169,^,^177,178^ Once ambivalence is uncovered, the clinician selectively elicits, supports, and strengthens the patient's “change talk” (e.g., reasons, ideas, needs for eliminating tobacco use) and “commitment language” (e.g., intentions to take action to change smoking behavior, such as not smoking in the home). MI researchers have found that having patients use their own words to commit to change is more effective than clinician exhortations, lectures, or arguments for quitting, which tend to increase rather than lessen patient resistance to change.^177^

The four general principles that underlie MI are: (1) express empathy, (2) develop discrepancy, (3) roll with resistance, and (4) support self-efficacy.^168,179^ Specific MI counseling strategies that are based on these principles are listed in Strategy B1. Because this is a specialized technique, it may be beneficial to have a member of the clinical staff receive training in motivational interviewing. The content areas that should be addressed in a motivational counseling intervention can be captured by the “5 R's”: relevance, risks, rewards, roadblocks, and repetition (Strategy B2). Research suggests that the “5 R's” enhance future quit attempts.^169,180^

Table B1 Strategy. Motivational interviewing strategies

Express empathy. | - Use open-ended questions to explore:; - The importance of addressing smoking or other tobacco use (e.g., “How important do you think it is for you to quit smoking?”); - Concerns and benefits of quitting (e.g., “What might happen if you quit?”); - Use reflective listening to seek shared understanding:; - Reflect words or meaning (e.g., “So you think smoking helps you to maintain your weight.”).; - Summarize (e.g., “What I have heard so far is that smoking is something you enjoy. On the other hand, your boyfriend hates your smoking, and you are worried you might develop a serious disease.”).; - Normalize feelings and concerns (e.g., “Many people worry about managing without cigarettes.”).; - Support the patient's autonomy and right to choose or reject change (e.g., “I hear you saying you are not ready to quit smoking right now. I'm here to help you when you are ready.”).
Develop discrepancy. | - Highlight the discrepancy between the patient's present behavior and expressed priorities, values, and goals (e.g., “It sounds like you are very devoted to your family. How do you think your smoking is affecting your children?”).; - Reinforce and support “change talk” and “commitment” language:; - “So, you realize how smoking is affecting your breathing and making it hard to keep up with your kids.”; - “It's great that you are going to quit when you get through this busy time at work.”; - Build and deepen commitment to change:; - “There are effective treatments that will ease the pain of quitting, including counseling and many medication options.”; - “We would like to help you avoid a stroke like the one your father had.”
Roll with resistance. | - Back off and use reflection when the patient expresses resistance:; - “Sounds like you are feeling pressured about your smoking.”; - Express empathy:; - “You are worried about how you would manage withdrawal symptoms.”; - Ask permission to provide information:; - “Would you like to hear about some strategies that can help you address that concern when you quit?”
Support self-efficacy. | - Help the patient to identify and build on past successes:; - “So you were fairly successful the last time you tried to quit.”; - Offer options for achievable small steps toward change:; - Call the quitline (1-800-QUIT-NOW) for advice and information.; - Read about quitting benefits and strategies.; - Change smoking patterns (e.g., no smoking in the home).; - Ask the patient to share his or her ideas about quitting strategies.

Table B2 Strategy. Enhancing motivation to quit tobacco—the “5 R's”

Relevance | Encourage the patient to indicate why quitting is personally relevant, being as specific as possible. Motivational information has the greatest impact if it is relevant to a patient's disease status or risk, family or social situation (e.g., having children in the home), health concerns, age, gender, and other important patient characteristics (e.g., prior quitting experience, personal barriers to cessation).
Risks | The clinician should ask the patient to identify potential negative consequences of tobacco use. The clinician may suggest and highlight those that seem most relevant to the patient. The clinician should emphasize that smoking low-tar/low-nicotine cigarettes or use of other forms of tobacco (e.g., smokeless tobacco, cigars, and pipes) will not eliminate these risks. Examples of risks are:; - Acute risks: Shortness of breath, exacerbation of asthma, increased risk of respiratory infections, harm to pregnancy, impotence, infertility.; - Long-term risks: Heart attacks and strokes, lung and other cancers (e.g., larynx, oral cavity, pharynx, esophagus, pancreas, stomach, kidney, bladder, cervix, and acute myelocytic leukemia), chronic obstructive pulmonary diseases (chronic bronchitis and emphysema), osteoporosis, long-term disability, and need for extended care.; - Environmental risks: Increased risk of lung cancer and heart disease in spouses; increased risk for low birth-weight, sudden infant death syndrome (SIDS), asthma, middle ear disease, and respiratory infections in children of smokers.
Rewards | The clinician should ask the patient to identify potential benefits of stopping tobacco use. The clinician may suggest and highlight those that seem most relevant to the patient. Examples of rewards follow:; - Improved health; - Food will taste better; - Improved sense of smell; - Saving money; - Feeling better about oneself; - Home, car, clothing, breath will smell better; - Setting a good example for children and decreasing the likelihood that they will smoke; - Having healthier babies and children; - Feeling better physically; - Performing better in physical activities; - Improved appearance, including reduced wrinkling/aging of skin and whiter teeth
Roadblocks | The clinician should ask the patient to identify barriers or impediments to quitting and provide treatment (problemsolving counseling, medication) that could address barriers. Typical barriers might include:; - Withdrawal symptoms; - Fear of failure; - Weight gain; - Lack of support; - Depression; - Enjoyment of tobacco; - Being around other tobacco users; - Limited knowledge of effective treatment options
Repetition | The motivational intervention should be repeated every time an unmotivated patient visits the clinic setting. Tobacco users who have failed in previous quit attempts should be told that most people make repeated quit attempts before they are successful.

## C. For the Patient Who Has Recently Quit

### Treatments for the Recent Quitter

Smokers who have recently quit face a high risk of relapse. Although most relapse occurs early in the quitting process,^96,^,^101,181^ some relapse occurs months or even years after the quit date.^181^–^184^ Numerous studies have been conducted to identify treatments that can reduce the likelihood of future relapse. These studies attempt to reduce relapse either by including special counseling or therapy in the cessation treatment, or by providing additional treatment to smokers who have previously quit. In general, such studies have failed to identify either counseling or medication treatments that are effective in lessening the likelihood of relapse,^185^ although there is some evidence that special mailings can reduce the likelihood of relapse.^186,187^ Thus, at present, the best strategy for producing high long-term abstinence rates appears to be use of the most effective cessation treatments available; that is, the use of evidence-based cessation medication during the quit attempt and relatively intense cessation counseling (e.g., four or more sessions that are 10 minutes or more in length).

Ex-smokers often report problems that have been worsened by smoking withdrawal or that coexisted with their smoking. If a clinician encounters a tobacco user who recently quit, the clinician might reinforce the patient's success at quitting, review the benefits of quitting, and assist the patient in resolving any residual problems arising from quitting (Strategy C1). Such expressions of interest and involvement on the part of the clinician might encourage the patient to seek additional help with cessation should she or he ultimately relapse. When the clinician encounters a patient who is abstinent from tobacco and is no longer engaged in cessation treatment, the clinician may wish to acknowledge a patient's success in quitting. The abstinent former smoker also may experience problems related to cessation that deserve treatment in their own right (see Strategy C2).

Table C1 Strategy. Intervening with the patient who has recently quit

The former tobacco user should receive congratulations on any success and strong encouragement to remain abstinent.

When encountering a recent quitter, use open-ended questions relevant to the topics below to discover if the patient wishes to discuss issues related to quitting:

- The benefits, including potential health benefits, the patient may derive fromcessation
- Any success the patient has had in quitting (duration of abstinence, reduction in withdrawal, etc.)
- The problems encountered or anticipated threats to maintaining abstinence (e.g., depression, weight gain, alcohol, other tobacco users in the household, significant stressors)
- A medication check-in, including effectiveness and side effects if the patient is still taking medication

Table C2 Strategy. Addressing problems encountered by former smokers

A patient who previously smoked might identify a problem that negatively affects health or quality of life. Specific problems likely to be reported by former smokers and potential responses follow:
Problems | Responses
Lack of support for cessation | - Schedule followup visits or telephone calls with the patient.; - Urge the patient to call the national quitline network (1-800-QUIT-NOW) or other local quitline.; - Help the patient identify sources of support within his or her environment.; - Refer the patient to an appropriate organization that offers counseling or support.
Negative mood or depression | - If significant, provide counseling, prescribe appropriate medication, or refer the patient to a specialist.
Strong or prolonged withdrawal symptoms | - If the patient reports prolonged craving or other withdrawal symptoms, consider extending the use of an approved medication or adding/combining medications to reduce strong withdrawal symptoms.
Weight gain | - Recommend starting or increasing physical activity.; - Reassure the patient that some weight gain after quitting is common and usually is self-limiting.; - Emphasize the health benefits of quitting relative to the health risks of modest weight gain.; - Emphasize the importance of a healthy diet and active lifestyle.; - Suggest low-calorie substitutes such as sugarless chewing gum, vegetables, or mints.; - Maintain the patient on medication known to delay weight gain (e.g., bupropion SR, NRTs—particularly 4-mg nicotine gum^147^—and lozenge.; - Refer the patient to a nutritional counselor or program.
Smoking lapses | - Suggest continued use of medications, which can reduce the likelihood that a lapse will lead to a full relapse.; - Encourage another quit attempt or a recommitment to total abstinence.; - Reassure that quitting may take multiple attempts, and use the lapse as a learning experience.; - Provide or refer for intensive counseling.