# Helpful Web Site Addresses

The inclusion of Web sites in this appendix is intended to assist readers in finding additional information regarding the treatment of tobacco use and dependence and related topics and does not constitute endorsement of the contents of any particular site. All Web sites listed are either Government-sponsored organizations or nonprofit foundations.

Addressing Tobacco in Healthcare (formerly Addressing Tobacco in Man-aged Care): www.atmc.wisc.edu

Agency for Healthcare Research and Quality: www.ahrq.gov

American Academy of Family Physicians: www.aafp.org

American Cancer Society: www.cancer.org

American College of Chest Physicians: www.chestnet.org

American Legacy Foundation: www.americanlegacy.org

American Lung Association: (maintains profiles of state tobacco control activities): www.lungusa.org

American Psychological Association: www.apa.org

Association for the Treatment of Tobacco Use and Dependence: www.attud.org

Campaign for Tobacco-Free Kids: www.tobaccofreekids.org

Chest Foundation: www.chestfoundation.org/tobaccoPrevention/index.php

Kaiser Family State Health Facts: www.statehealthfacts.org

Medicare and Medicaid: www.cms.hhs.gov/mcd/viewdecisionmemo.asp?id=130 and www.cms.hhs.gov/Smoking Cessation

North American Quitline Consortium (NAQC): www.Naquitline.org

National Cancer Institute: www.nci.nih.gov

National Guideline Clearinghouse: www.guideline.gov

National Heart, Lung, and Blood Institute: www.nhlbi.nih.gov

National Institute on Drug Abuse: www.nida.nih.gov

Office on Smoking and Health at the Centers for Disease Control and Prevention: www.cdc.gov/tobacco

Robert Wood Johnson Foundation: www.rwjf.org

Society for Research on Nicotine and Tobacco: www.srnt.org

TobaccoFree Nurses: www.tobaccofreenurses.org

Tobacco Technical Assistance Consortium: www.ttac.org

University of Wisconsin Center for Tobacco Research and Intervention: www.ctri.wisc.edu

World Health Organization: www.who.int

World Health Organization - Tobacco Atlas: www.who.int/tobacco/statistics/tobacco_atlas/en