# General Strategies

General Strategy 1. Common elements of problem-solving/skills-training smoking cessation treatments

General Strategy 1. Common elements of problem-solving/skills-training smoking cessation treatments

Problem-solving treatment component | Examples
Recognition of danger situations -- Identification of events, internal states, or activities that are thought to increase the risk of smoking or relapse. | - Being around other smokers; - Being under time pressure; - Getting into an argument; - Experiencing urges or negative moods; - Drinking alcohol
Coping skills -- Identification and practice of coping or problem-solving skills. Typically, these skills are intended to cope with danger situations. | - Learning to anticipate and avoid danger situations; - Learning cognitive strategies that will reduce negative moods; - Accomplishing lifestyle changes that reduce stress, improve quality of life, or produce pleasure; - Learning cognitive and behavioral activities that distract attention from smoking urges
Basic information -- Provision of basic information about smoking and successful quitting. | - The nature/timecourse of withdrawal; - The addictive nature of smoking; - The fact that any smoking (even a single puff) increases the likelihood of full relapse

General Strategy 2. Common elements of supportive smoking cessation treatments

General Strategy 2. Common elements of supportive smoking cessation treatments

Supportive treatment component | Examples
Encourage the patient in the quit attempt. | - Note that effective cessation treatments are now available.; - Note that half of all people who have ever smoked, have now quit.; - Communicate belief in patient's ability to quit.
Communicate caring and concern | - Ask about how patient feels about quitting.; - Directly express concern and willingness to help.; - Be open to the patient's expression of fears of quitting, difficulties experienced, and ambivalent feelings.
Encourage the patient to talk about the quitting process. | Ask about:; - Reasons the patient wants to quit; - Difficulties encountered while quitting; - Success the patient has achieved; - Concerns or worries about quitting
Provide basic information about smoking and successful quitting. | - The nature/timecourse of withdrawal; - The addictive nature of smoking; - The fact that any smoking (even a single puff) increases the likelihood of full relapse

General Strategy 3. Suggestions on the clinical use of the nicotine patch

General Strategy 3. Suggestions on the clinical use of the nicotine patch

Patient selection | Appropriate as a primary pharmacotherapy for smoking cessation. For suggestions regarding use in special populations, see General Strategy 4.
Precautions | Pregnancy -- Pregnant smokers should first be encouraged to attempt cessation without pharmacologic treatment. The nicotine patch should be used during pregnancy only if the increased likelihood of smoking cessation, with its potential benefits, outweighs the risk of nicotine replacement and potential concomitant smoking. Similar factors should be considered in lactating women.
Precautions | Cardiovascular diseases -- Although not an independent risk factor for acute myocardial events, the nicotine patch should be used only after consideration of risks and benefits among particular cardiovascular patient groups: those in the immediate (within 4 weeks) postmyocardial infarction period, those with serious arrhythmias, and those with severe or worsening angina pectoris.
Precautions | Skin reactions -- Up to 50% of patients using the nicotine patch will have a local skin reaction. Skin reactions are usually mild and self-limiting, but may worsen over the course of therapy. Local treatment with hydrocortisone cream (5%) or triamcinolone cream (.5%) and rotating patch sites may ameliorate such local reactions. In less than 5% of patients do such reactions require the discontinuation of nicotine patch treatment.
Dosage | Treatment of 8 weeks or less has been shown to be as efficacious as longer treatment periods (Fiore, Smith, Jorenby, et al., 1994). Based on this finding, the following treatment schedules are suggested as reasonable for most smokers. Clinicians should consult the package insert for other treatment suggestions. Finally, clinicians should consider individualizing treatment based on specific patient characteristics, such as previous experience with the patch, amount smoked, degree of addictiveness, etc. [a]
Brand | Duration | Dosage
Nicoderm and Habitrol | 4 weeks then 2 weeks then 2 weeks | 21 mg/24 hours 14 mg/24 hours 7 mg/24 hours
Prostep | 4 weeks then 4 weeks | 22 mg/24 hours 11 mg/24 hours
Nicotrol | 4 weeks then 2 weeks then 2 weeks | 15 mg/16 hours 10 mg/16 hours 5 mg/16 hours
Prescribing instructions | No smoking while on the patch.
Prescribing instructions | Location -- At the start of each day, the patient should place a new patch on a relatively hairless location between the neck and waist.
Prescribing instructions | Activities -- No restrictions while using the patch.
Prescribing instructions | Time -- Patches should be applied as soon as patients waken on their quit day.

[a] These dosage recommendations are based on a review of the published research literature and do not necessarily conform to packet insert information.

General Strategy 4. Clinical guidelines for prescribing nicotine replacement products

General Strategy 4. Clinical guidelines for prescribing nicotine replacement products

Who should receive nicotine replacement? | Available research shows that nicotine replacement generally increases rates of smoking cessation. Therefore, except in the presence of serious medical precautions, the clinician should encourage the use of nicotine replacement with patients who smoke. Little research is available on the use of nicotine replacement with light smokers (e.g., those smoking 10-15 cigarettes/day or less). If nicotine replacement is to be used with light smokers, a lower starting dose of the nicotine patch or nicotine gum should be considered.
Should nicotine replacement therapy be tailored to the individual smoker? | Research does not support the tailoring of nicotine patch therapy (except with light smokers as noted above). Patients should be prescribed the patch dosages outlined in General Strategy 3.
Should nicotine replacement therapy be tailored to the individual smoker? | Research supports tailoring nicotine gum treatment. Specifically, 4-mg gum, as opposed to 2-mg gum, can be used with patients who are highly dependent on nicotine (e.g., those smoking more than 20 cigarettes/day, those who smoke within 30 minutes of awakening, and those who report that it is difficult to refrain from smoking where it is forbidden; see Heatherton, Kozlowski, Frecker, et al., 1991). Clinicians may also recommend the higher gum dosage if patients request it or have failed to quit using the 2-mg gum.
Should patients be encouraged to use the nicotine patch or nicotine gum? | Although both pharmacotherapies are efficacious, nicotine patch therapy is preferable for routine clinical use. This preference is based on the following comparisons with nicotine gum therapy:; - Nicotine patch therapy is associated with fewer compliance problems that interfere with effective use.; - Nicotine patch therapy requires less clinician time and effort to train patients in its effective use.; The following factors support the use of nicotine gum:; - Patient preference.; - Previous failure with the nicotine patch.; - Contraindications specific to nicotine patch use (e.g., severe skin reactions).

General Strategy 5. Suggestions for the clinical use of nicotine gum

General Strategy 5. Suggestions for the clinical use of nicotine gum

Patient selection | Appropriate as a primary pharmacotherapy for smoking cessation. For suggestions regarding use in special populations, see General Strategy 4.
Precautions | Pregnancy -- Pregnant smokers should first be encouraged to attempt cessation without pharmacologic treatment. Nicotine gum should be used during pregnancy only if the increased likelihood of smoking cessation, with its potential benefits, outweighs the risk of nicotine replacement and potential concomitant smoking.
Precautions | Cardiovascular diseases -- Although not an independent risk factor for acute myocardial events, nicotine gum should be used only after consideration of risks and benefits among particular cardiovascular patient groups: those in the immediate (within 4 weeks) postmyocardial infarction period, those with serious arrhythmias, and those with serious or worsening angina pectoris.
Precautions | Side effects -- Common side effects of nicotine chewing gum include mouth soreness, hiccups, dyspepsia, and jaw ache. These effects are generally mild and transient, and can often be alleviated by correcting the patient's chewing technique (see Prescribing instructions below).
Dosage | Nicotine gum is available in 2-mg and 4-mg (per piece) doses. Patients should be prescribed the 2-mg gum except in special circumstances outlined in General Strategy 4. The gum is most commonly prescribed for the first few months of a quit attempt. Clinicians should tailor the duration of therapy to fit the needs of each patient. Patients using the 2-mg strength should use not more than 30 pieces per day, whereas those using the 4-mg strength should not exceed 20 pieces per day. (Information on tailoring the dose of nicotine gum is presented in General Strategy 4.)
Prescribing instructions | No smoking while using the gum.
Prescribing instructions | Chewing technique -- Gum should be chewed slowly until a "peppery" taste emerges, then "parked" between cheek and gum to facilitate nicotine absorption through the oral mucosa. Gum should be slowly and intermittently "chewed and parked" for about 30 minutes.
Prescribing instructions | Absorption -- Acidic beverages (e.g., coffee, juices, soft drinks) interfere with the buccal absorption of nicotine, so eating and drinking anything except water should be avoided for 15 minutes before and during chewing.
Prescribing instructions | Scheduling of dose -- Patients often do not use enough gum to get the maximum benefit: they chew too few pieces per day and they do not use the gum for a sufficient number of weeks. Instructions to chew the gum on a fixed schedule (at least one piece every 1-2 hours) for at least 1-3 months may be more beneficial than ad lib use.

General Strategy 6. Components of clinical interventions designed to enhance motivation to quit smoking: the "4 Rs"

General Strategy 6. Components of clinical interventions designed to enhance motivation to quit smoking: the "4 Rs"

Relevance | Motivational information given to a patient has the greatest impact if it is relevant to a patient's disease status, family or social situation (e.g., having children in the home), health concerns, age, gender, and other important patient characteristics (e.g., prior quitting experience).
Risks | The clinician should ask the patient to identify the potential negative consequences of smoking. The clinician may suggest and highlight those that seem most relevant to the patient. The clinician should emphasize that smoking low-tar/low-nicotine cigarettes or use of other forms of tobacco (e.g., smokeless tobacco, cigars, pipes) will not eliminate these risks. Examples of risks follow:; - Acute risks: Shortness of breath, exacerbation of asthma, impotence, infertility, increased serum carbon monoxide; - Long-term risks: Heart attacks and strokes, lung and other cancers (larynx, oral cavity, pharynx, esophagus, pancreas, bladder, cervix, leukemia), chronic obstructive pulmonary diseases (chronic bronchitis and emphysema); - Environmental risks: Increased risk of lung cancer in spouse and children; higher rates of smoking by children of smokers; increased risk for SIDS, asthma, middle ear disease, and respiratory infections in children of smokers
Rewards | The clinician should ask the patient to identify the potential benefits of quitting smoking. The clinician may suggest and highlight those that seem most relevant to the patient. Examples of rewards follow:; - Improved health; - Food will taste better; - Improved sense of smell; - Save money; - Feel better about yourself; - Home, car, breath will smell better; - Can stop worrying about quitting; - Set a good example for kids; - Have healthy babies and children; - Not worry about exposing others to smoke; - Feel better physically; - Freedom from addiction; - Perform better in sports
Repetition | The motivational intervention should be repeated every time an unmotivated patient visits the clinic setting.

## General Strategy 7. Components of minimal practice relapse prevention interventions

1. Every ex-smoker undergoing relapse prevention should receive congratulations, encouragement, and a statement of concern on the part of the clinician that the patient remain abstinent.
2. The clinician should encourage the patient's active discussion of the topics listed below. The clinician should ask the patient open-ended questions designed to initiate the patient's problem solving on these topics (e.g., How has stopping smoking helped you?):

- The benefits, including potential health benefits, the patient may derive from cessation.
- Any success the patient has had in quitting (duration of abstinence, reduction in withdrawal, etc.).
- The problems encountered or anticipated in maintaining abstinence (e.g., depression, weight gain).
- Anticipated problems or threats to maintaining abstinence.

General Strategy 8. Components of prescriptive relapse prevention intervention

General Strategy 8. Components of prescriptive relapse prevention intervention

During relapse prevention, an inquiry about problems encountered in maintaining abstinence might lead the clinician to make recommendations or offer treatment designed to address specific problems reported by the patient. Specific problems likely to be reported by patients and potential responses follow:
Weight gain -- The clinician might make dietary, exercise, or lifestyle recommendations, or might refer the patient to a specialist or program. The patient can be reassured that some weight gain after quitting is common and that significant dietary restrictions soon after quitting may be counterproductive.
Negative mood or depression -- If significant, the clinician might prescribe appropriate medications or refer the patient to a specialist.
Prolonged withdrawal symptoms -- If the patient reports prolonged craving or other withdrawal symptoms, the clinician might consider extending nicotine replacement therapy.
Lack of support for cessation -- The clinician might schedule followup phone calls with the patient, help the patient identify sources of support within his/her environment, or refer the patient to an appropriate organization that offers cessation counseling or support.

General Strategy 9. Clinical issues when assisting a pregnant patient in smoking cessation

General Strategy 9. Clinical issues when assisting a pregnant patient in smoking cessation

Clinical issues | Rationale
Quit early in pregnancy if possible. | Early quitting provides the greatest benefit to the fetus.
Quit anytime during pregnancy. | Fetus benefits even when quitting later in pregnancy.
Stress early benefits to quitting. | Both woman and fetus will benefit immediately.
Provide pregnancy-related motivational messages. | These are associated with higher quit rates.
Be alert to patients' minimizing or denying tobacco use. | Minimizing or denying smoking is common among pregnant women who smoke.
Assess for relapse and use relapse prevention. | Postpartum relapse rates are high even if a woman maintains abstinence throughout pregnancy (see General Strategies 6 and 7). Relapse prevention may start during pregnancy.

General Strategy 10. Clinician statements to help a patient prepare for, and cope with, postcessation weight gain

General Strategy 10. Clinician statements to help a patient prepare for, and cope with, postcessation weight gain

"The great majority of smokers gain weight once they quit smoking. However, even without special attempts at dieting or exercise, weight gain is usually limited to less than 10 lbs."
"There is evidence that smokers will gain weight once they quit smoking even if they do not eat more. Weight gain appears to be a natural part of quitting smoking."
"The amount of weight you will likely gain from quitting will be a minor health risk compared with the risks of continued smoking."
"Try to put your concerns about weight on the back burner. You are most likely to be successful if you first try to quit smoking, and then later take steps to reduce your weight. Tackle one problem at a time! After you have quit smoking successfully we can talk about how to reduce your weight."
"I know weight is important to you, and that you don't want to gain a lot of weight. However, temporarily -- just until you are confident that you have quit smoking for good -- let's focus on strategies to get you healthy rather than on weight. Think about eating plenty of fruit and vegetables, getting regular exercise, getting enough sleep, and not eating a lot of fats. Right now, this is probably the best thing you can do for both your weight and your smoking. Eat plenty of healthy foods -- don't starve yourself!"
"While you may gain some weight after quitting smoking, compare the importance of this with the added years of healthy living you will gain, your better appearance (less wrinkled skin, whiter teeth), fresher breath, and good feelings about quitting."

## General Strategy 11. Suggested interventions for clinicians to prevent the initiation of tobacco use

- Begin in the early elementary school grades to discuss tobacco use and its negative effects -- especially the short-term negative effects.
- Ask the child if s/he has experimented with tobacco.
- Identify the advantages of not smoking, including those most appropriate for the patient's age and developmental stage.
- Discuss the fact that the child eventually will encounter peers who smoke, and discuss ways in which the child might resist peer pressure to try tobacco products.

For youngsters approaching middle school/junior high school age, provide the following information:

- Most kids don't smoke or use smokeless tobacco.
- All forms of tobacco (snuff, cigarettes, dip, etc.) are extremely addictive, and most teens who use tobacco are addicted to nicotine.
- Addiction to tobacco takes away one's independence.
- Smokeless tobacco is not a safe alternative to smoking, because it is addicting and causes oral cancer.
- Smoking makes a person smell bad, stains teeth and skin, causes shortness of breath, decreases athletic performance, ruins clothes, and is a major cause of fires and deaths.
- Smoking causes health problems in many young people, including chronic cough and sore throat.
- Smoking won't make a person rugged, sexy, "cool," or successful.
- Tobacco use is a gateway to other drug use, and addiction to nicotine may make a person more susceptible to trying other dangerous drugs.
- Tobacco is expensive -- spending money on tobacco will mean less money for other things (e.g., books, clothes, make-up, music, movies, sports).
- There are other ways of being different without taking up a habit that is addicting and has such severe, long-term consequences.