# Strategies for Health Care Administrators, Insurers, and Purchasers

For health care administrators, insurers, and purchasers: Strategy 1. Implement a tobacco-user identification system in every clinic

For health care administrators, insurers, and purchasers: Strategy 1. Implement a tobacco-user identification system in every clinic

Action | Strategies for implementation
Implement an office-wide system that ensures that, for EVERY patient at EVERY clinic visit, tobacco-use status is queried and documented. | Office system change: | Expanding the Vital Signs to include tobacco use (see Strategy 1 for the Primary Care Clinician).
Implement an office-wide system that ensures that, for EVERY patient at EVERY clinic visit, tobacco-use status is queried and documented. | Responsible staff: | Nurse, medical assistant, receptionist, or other individual already responsible for measuring the vital signs--no additional staff requirements. These staff must be instructed regarding the frequency and importance of this activity.
Implement an office-wide system that ensures that, for EVERY patient at EVERY clinic visit, tobacco-use status is queried and documented. | Frequency of utilization: | Every visit for every patient regardless of the reason that brought the individual to the clinic. [a] In other words, whenever health care staff collect the traditional vitals signs data, they also query and document tobacco use.
Implement an office-wide system that ensures that, for EVERY patient at EVERY clinic visit, tobacco-use status is queried and documented. | System implementation steps: | Preprint progress note paper or preprogram computer record for every patient visit to include tobacco use along with the traditional vital signs. A vital sign stamp can also be effective. Alternatives to the vital sign stamp are to place tobacco-use status stickers on all patient charts or to indicate smoking status using computer reminder systems.
VITAL SIGNS

[a] Repeated assessment is not necessary in the case of the adult who has never smoked or not smoked for many years, and for whom this information is clearly documented in the medical record.

For health care administrators, insurers, and purchasers: Strategy 2. Provide education, resources, and feedback to promote provider intervention

For health care administrators, insurers, and purchasers: Strategy 2. Provide education, resources, and feedback to promote provider intervention

Action | Strategies for implementation
Health care systems should ensure that clinicians have the knowledge and training to treat smoking, that clinicians and patients have cessation resources, and that clinicians are given feedback about their cessation practices. | Educate -- On a regular basis, offer lectures/seminars/in-services with CME and other credit for smoking cessation treatment.
| Resources -- Have patient self-help materials, as well as nicotine replacement "starter kits," readily available in every exam room.
| Provide feedback -- Drawing on data from chart audits, electronic medical records, computerized patient databases, and so on, evaluate the degree to which clinicians are identifying, documenting, and treating patients who smoke, and provide feedback to clinicians about their level of intervention.

For health care administrators, insurers, and purchasers: Strategy 3. Dedicate staff to provide smoking cessation treatment and assess the delivery of this treatment in staff performance evaluations

For health care administrators, insurers, and purchasers: Strategy 3. Dedicate staff to provide smoking cessation treatment and assess the delivery of this treatment in staff performance evaluations

Action | Strategies for implementation
Clinical sites should communicate to staff the importance of intervening with smokers and should designate one staff person (e.g., nurse, medical assistant, or other clinician) to coordinate and deliver smoking cessation treatments. | Communicate to each staff member (e.g., nurse, medical assistant, or other clinician) his or her responsibilities in the delivery of smoking cessation services.
| Designate a smoking cessation treatment coordinator for every clinical site.
| Delineate the responsibilities of the smoking cessation coordinator, including instructing patients on the effective use of cessation treatments (e.g., nicotine replacement therapy, telephone calls to and from prospective quitters, and scheduled followup visits, especially in the immediate post-quit period).

For health care administrators, insurers, and purchasers: Strategy 4. Promote hospital policies that support and provide smoking cessation services

For health care administrators, insurers, and purchasers: Strategy 4. Promote hospital policies that support and provide smoking cessation services

Action | Strategies for implementation
Provide smoking cessation inpatient consultation services to all smokers admitted to a hospital. | Implement a system to identify and document the tobacco-use status of all hospitalized patients.
Provide smoking cessation inpatient consultation services to all smokers admitted to a hospital. | Offer cessation treatment to all hospitalized patients who use tobacco.
Provide smoking cessation inpatient consultation services to all smokers admitted to a hospital. | Identify a clinician(s) to deliver smoking cessation inpatient consultation services for every hospital.
Provide smoking cessation inpatient consultation services to all smokers admitted to a hospital. | Reimburse providers for smoking cessation inpatient consultation services.
Provide smoking cessation inpatient consultation services to all smokers admitted to a hospital. | Expand hospital formularies to include effective smoking cessation pharmacotherapy such as the nicotine patch and nicotine gum.
Provide smoking cessation inpatient consultation services to all smokers admitted to a hospital. | Ensure compliance with JCAHO regulations mandating that all sections of the hospital be entirely smoke-free.
Provide smoking cessation inpatient consultation services to all smokers admitted to a hospital. | Educate all hospital staff regarding nicotine withdrawal, including effective treatments such as nicotine replacement therapy and counseling.

For health care administrators, insurers, and purchasers: Strategy 5. Include smoking cessation treatments (both pharmacotherapy and counseling), identified as effective in this guideline, as paid services for all subscribers of health insurance packages

For health care administrators, insurers, and purchasers: Strategy 5. Include smoking cessation treatments (both pharmacotherapy and counseling), identified as effective in this guideline, as paid services for all subscribers of health insurance packages

Action | Strategies for implementation
Provide all insurance subscribers coverage for effective smoking cessation treatments, including pharmacotherapy (nicotine replacement therapy) and counseling. | Cover -- Include effective smoking cessation treatments (both pharmacotherapy and counseling) as part of the basic benefits package for all individual, group, and HMO insurance packages.
Provide all insurance subscribers coverage for effective smoking cessation treatments, including pharmacotherapy (nicotine replacement therapy) and counseling. | Evaluate -- Include the provision of smoking cessation treatment as part of "report cards" for managed care organizations and other insurers (e.g., Health Plan Employer Data and Information Set (HEDIS)).
Provide all insurance subscribers coverage for effective smoking cessation treatments, including pharmacotherapy (nicotine replacement therapy) and counseling. | Educate -- Inform subscribers of the availability of covered smoking cessation services and encourage patients to use these services.

For health care administrators, insurers, and purchasers: Strategy 6. Reimburse fee-for-service clinicians for delivery of effective smoking cessation treatments and include these interventions among the defined duties of salaried clinicians

For health care administrators, insurers, and purchasers: Strategy 6. Reimburse fee-for-service clinicians for delivery of effective smoking cessation treatments and include these interventions among the defined duties of salaried clinicians

Action | Strategies for implementation
Reimburse fee-for-service clinicians for delivery of effective smoking cessation treatments; include smoking cessation treatments in the defined duties of salaried clinicians. | Include smoking cessation treatment as a reimbursable activity for fee-for-service providers.
Reimburse fee-for-service clinicians for delivery of effective smoking cessation treatments; include smoking cessation treatments in the defined duties of salaried clinicians. | Inform fee-for-service clinicians that they will be reimbursed for using effective smoking cessation treatments with every patient who uses tobacco.
Reimburse fee-for-service clinicians for delivery of effective smoking cessation treatments; include smoking cessation treatments in the defined duties of salaried clinicians. | Include smoking cessation intervention in the job description and performance evaluation of salaried clinicians.