# Strategies for the Tobacco Cessation Specialist

## For the specialist: Strategy 1. Findings relevant to the specialist's implementation of intensive cessation programs

- There is a strong dose-response relation between counseling intensity and cessation success. In general, the more intense the cessation intervention, the greater the rate of smoking cessation. Treatments may be made more intense by increasing (a) the length of individual treatment sessions and (b) the number of treatment sessions and number of weeks over which treatment is delivered.
- Valid predictors of outcome are available. For instance, high levels of dependence, psychiatric comorbidity, and low levels of motivation to quit all predict greater likelihood of relapse. These measures might be used to adjust treatment intensity, to match patients with particular types of treatment, or for research purposes.
- Many different types of cessation providers (physicians, nurses, dentists, psychologists, pharmacists, etc.) are effective in increasing rates of smoking cessation, and involving multiple types of providers appears to enhance cessation rates.
- Both individual and group counseling are effective smoking cessation formats.
- Particular counseling contents are especially effective. Problem-solving/skills-training approaches and the provision of intratreatment support are associated with significant increases in cessation rates, as are aversive smoking techniques (e.g., rapid smoking).
- Pharmacotherapy in the form of nicotine patch or nicotine gum therapy consistently increases smoking cessation rates regardless of the level of adjuvant behavioral or psychosocial interventions. Therefore, its use should be encouraged.
- Smoking cessation interventions are effective across diverse populations: across gender, racial, and ethnic groups; across age groups; in pregnant women; etc.

For the specialist: Strategy 2. Recommendations regarding intensive smoking cessation programs

Assessment | Assessments should determine whether smokers are motivated to quit smoking via an intensive cessation program. Other assessments can provide information useful in counseling (e.g., stress level, presence of comorbidity; see Chapter 3, Specialized Assessment).
Program clinicians | Multiple types of clinicians should be used. One strategy would be to have a medical/health care clinician deliver messages about health risks and benefits, and nonmedical clinicians deliver psychosocial or behavioral interventions.
Program intensity | Because of evidence of a strong dose-response relation, the intensity of the program should be:
Program intensity | Session length -- at least 20-30 minutes in length [a]
Program intensity | Number of sessions -- at least 4-7 sessions
Program intensity | Length in weeks -- at least 2 weeks, preferably more than 8 weeks
Program format | Either individual or group counseling may be used. Use of adjuvant self-help material is optional. Followup assessment procedures should be used (see Chapter 3).
Counseling content | Counseling should involve either or both problem-solving/skills-training content as well as social support delivered during treatment sessions (see Chapter 3, subsection on Content of Smoking Cessation Interventions). In addition, content should target motivation to quit and relapse prevention (see Chapter 4).
Pharmacotherapy | Except in special circumstances, every smoker should be offered nicotine replacement.
Pharmacotherapy | Encourage the use of nicotine patch or nicotine gum therapy for smoking cessation (see General Strategies 3 and 5 for specific instructions and precautions).
Population | Intensive intervention programs may be used with all smokers willing to enter such programs.

[a] Session length of 20-30 minutes was recommended because most trials of effective smoking cessation counseling used sessions of at least this length