# Strategies for the Primary Care Physician

For the primary care clinician: Strategy 1. Ask--systematically identify all tobacco users at every visit

For the primary care clinician: Strategy 1. Ask--systematically identify all tobacco users at every visit

Action | Strategies for implementation
Implement an office-wide system that ensures that, for EVERY patient at EVERY clinic visit, tobacco-use status is queried and documented. [a] | Expand the vital signs to include tobacco use.; - Data collected by health care team.; - Implemented using preprinted progress note paper that includes the expanded vital signs, a vital signs stamp, or, for computerized records, includes an item assessing tobacco-use status.
Implement an office-wide system that ensures that, for EVERY patient at EVERY clinic visit, tobacco-use status is queried and documented. [a]
VITAL SIGNS
Alternatives to the vital sign stamp are to place tobacco-use status stickers on all patient charts or to indicate smoking status using computer reminder systems.

[a] Repeated assessment is not necessary in the case of the adult who has never smoked or not smoked for many years, and for whom this information is clearly documented in the medical record.

For the primary care clinician: Strategy 2. Advise -- strongly urge all smokers to quit

For the primary care clinician: Strategy 2. Advise—strongly urge all smokers to quit

Action | Strategies for implementation
In a clear, strong, and personalized manner, urge every smoker to quit. | Advice should be:; - Clear -- "I think it is important for you to quit smoking now and I will help you." "Cutting down while you are ill is not enough."; - Strong -- "As your clinician, I need you to know that quitting smoking is the most important thing you can do to protect your current and future health."; - Personalized -- Tie smoking to current health/illness, and/or the social and economic costs of tobacco use, motivation level/readiness to quit, and/or the impact of smoking on children and others in the household.; Encourage clinic staff to reinforce the cessation message and support the patient's quit attempt.

For the primary care clinician: Strategy 3. Identify smokers willing to make a quit attempt

For the primary care clinician: Strategy 3. Identify smokers willing to make a quit attempt

Action | Strategies for implementation
Ask every smoker if he or she is willing to make a quit attempt at this time. | - If the patient is willing to make a quit attempt at this time, provide assistance (see Strategy 4 for the Primary Care Clinician).; - If the patient prefers a more intensive treatment or the clinician believes intensive treatment is appropriate, refer to interventions administered by a smoking cessation specialist and follow up with the patient regarding quitting (see Strategy 5 for the Primary Care Clinician and Chapter 2, second section).; - If the patient clearly states he/she is not willing to make a quit attempt at this time, provide a motivational intervention (see Chapter 4, first section). Also, if the patient is a member of a special population (e.g., adolescent, pregnant smoker, racial/ethnic minority), additional information is provided in Chapter 5.

For the primary care clinician: Strategy 4. Assist -- aid the patient in quitting

For the primary care clinician: Strategy 4. Assist—aid the patient in quitting

Action | Strategies for implementation
Help the patient with a quit plan. | Set a quit date -- Ideally, the quit date should be within 2 weeks, taking patient preference into account.A patient's preparations for quitting:; - Inform family, friends, and co-workers of quitting and request understanding and support.; - Remove cigarettes from your environment. Prior to quitting, avoid smoking in places where you spend a lot of time (e.g., home, car).; - Review previous quit attempts. What helped you? What led to relapse?; - Anticipate challenges to planned quit attempt, particularly during the critical first few weeks. These include nicotine withdrawal symptoms.
Encourage nicotine replacement therapy except in special circumstances. | Encourage the use of nicotine patch or nicotine gum therapy for smoking cessation (see General Strategies 3 and 5 for specific instructions and precautions).
Give key advice on successful quitting. | Abstinence -- Total abstinence is essential. "Not even a single puff after the quit date."
Give key advice on successful quitting. | Alcohol -- Drinking alcohol is highly associated with relapse. Those who stop smoking should review their alcohol use and consider limiting/abstaining from alcohol during the quit process.
Give key advice on successful quitting. | Other smokers in the household -- The presence of other smokers in the household, particularly a spouse, is associated with lower success rates. Patients should consider quitting with their significant others and/or developing specific plans to stay quit in a household where others still smoke.
Provide supplementary materials. | Sources -- Federal agencies, including AHCPR; nonprofit agencies (ACS, ALA, AHA); or local/state health departments (see Attachment for details).
Provide supplementary materials. | Type -- Culturally/racially/educationally/age appropriate for the patient.
Provide supplementary materials. | Location -- Readily available in every clinic office.

For the primary care clinician: Strategy 5. Arrange -- schedule followup contact

For the primary care clinician: Strategy 5. Arrange—schedule followup contact

Action | Strategies for implementation
Schedule followup contact, either in person or via telephone. | - Timing -- Followup contact should occur soon after the quit date, preferably during the first week. A second followup contact is recommended within the first month. Schedule further followup contacts as indicated.
Schedule followup contact, either in person or via telephone. | - Actions during followup visit -- Congratulate success. If smoking occurred, review circumstances and elicit recommitment to total abstinence. Remind patient that a lapse can be used as a learning experience. Identify problems already encountered and anticipate challenges in the immediate future. Assess nicotine replacement therapy use and problems. Consider referral to a more intense or specialized program (see Chapter 4, second section).