# Attachment: National Network of Tobacco Prevention and Control Contacts

- National Cancer Institute
- Office of Cancer Communications
- Building 31, Room 10A24
- Bethesda, MD 20892
- Telephone: 1-800-4-CANCER

- Office on Smoking and Health
- National Center for Chronic Disease Prevention and Health Promotion
- Centers for Disease Control and Prevention
- Mail Stop K-50
- 4770 Buford Highway, NE
- Atlanta, GA 30341-3742
- Telephone (770) 488-5705

- ALABAMA
- Mobile County Health Department
- Bureau of Health Promotion
- Administrative Services
- P.O. Box 2867
- Mobile, AL 36652
- Telephone (334) 690-8186
- FAX (334) 432-7443

- Federal Express Address:
- 251 N. Bayou St.
- Mobile, AL 36603

- ALASKA
- Manager, Health Promotion Program
- Division of Public Health
- Department of Health and Social Services
- P.O. Box 110614
- Juneau, AK 99811-0614
- Telephone (907) 465-3140
- FAX (907) 465-2270

- Federal Express Address:
- 333 Willoughby St., Rm. 713
- Juneau, AK 99801

- ARKANSAS
- Director
- Office of Tobacco Control and Prevention
- 4815 W. Markham St.
- Little Rock, AR 72205
- Telephone (501) 661-2783
- FAX (501) 661-2082

- ARIZONA
- Program Director
- Tobacco Use Prevention and Control Program
- Office of Health Promotion and Education
- 1400 W. Washington St.
- Phoenix, AZ 85007
- Telephone (602) 542-7234
- FAX (602) 542-0141

- CALIFORNIA
- California Department of Health Services
- 744 P St.
- P.O. Box 942732
- Sacramento, CA 94234-7320
- Telephone (916) 322-4787
- FAX (916) 327-5424

- COLORADO
- ASSIST Project Manager
- Colorado Department of Health
- 4300 Cherry Creek Dr., S.
- Denver, CO 80222-1530
- Telephone (303) 692-2515
- FAX (303) 782-0095

- CONNECTICUT
- Health Program Supervisor
- Department of Public Health and Addiction Services
- 150 Washington St.
- Hartford, CT 06106
- Telephone (203) 566-6618
- FAX (203) 566-1217

- DELAWARE
- Prevention Coordinator
- Department of Health and Social Services
- P.O. Box 637
- Dover, DE 19903
- Telephone (302) 739-4724
- FAX (302) 739-6617
- Federal Express Address:
- Jessie Cooper Bldg.
- Federal and Water Streets
- Dover, DE 19901

- DISTRICT OF COLUMBIA
- Public Health Educator
- Department of Human Services
- 2nd Fl.
- 800 Ninth Street, S.W.
- Washington, DC 20024
- Telephone (202)-645-5556
- FAX (202)-645-0526

- FLORIDA
- Program Administration
- HRS Health Promotion and Wellness
- Building 2-HSH, Room 321
- 1317 Winewood Blvd.
- Tallahassee, FL 32399-0700
- Telephone (904) 487-3220
- FAX (904) 488-6495

- GEORGIA
- Tobacco Prevention Program Manager
- Department of Human Resources
- Tobacco Prevention Education Program
- 2 Peachtree St., 6th Fl.
- Atlanta, GA 30303
- Telephone (404) 657-2570
- FAX (404) 657-6631

- GUAM
- Health Educator Administrator
- Department of Public Health and Social Services
- P.O. Box 2816
- Agana, Guam 96910
- Telephone (671) 734-7129
- FAX (671) 734-5910

- HAWAII
- Department of Health
- 952 N. King St., Bay 06
- Honolulu, HI 96817
- Telephone (808) 832-5951
- FAX (808) 832-5955

- IDAHO
- Health Promotion Coordinator
- Idaho Department of Health and Welfare
- P.O. Box 83728
- 450 W. State St.
- Boise, ID 83720-0036
- Telephone (208) 334-4936
- FAX (208) 334-6573

- ILLINOIS
- Chief Public Health Educator
- Illinois Department of Public Health
- Division of Health Promotion
- 535 W. Jefferson St.
- Springfield, IL 62761
- Telephone (217) 785-2060
- FAX (217) 782-1235

- INDIANA
- Director, ASSIST Project
- Division of Health Education
- Indiana Department of Health
- 1330 W. Michigan St.
- P.O. Box 1964
- Indianapolis, IN 46206-1964
- Telephone (317) 633-0267
- FAX (317) 633-0776
- Federal Express Address:
- Drop P.O. Box

- IOWA
- Director, Division of Substance Abuse and Health Promotion
- Iowa Department of Public Health
- Lucas State Office Bldg.
- Des Moines, IA 50319-0075
- Telephone (515) 281-7248
- FAX (515) 281-4535

- KANSAS
- Office of Chronic Disease and Health Promotion
- Kansas Department of Health and Environment
- 900 S.W. Jackson St.
- Topeka, KS 66612-1290
- Telephone (913) 296-1233
- FAX (913) 296-8059

- KENTUCKY
- Tobacco Control Coordinator
- Kentucky Department for Health Services
- 275 E. Main St.
- Frankfort, KY 40621
- Telephone (502) 564-7243
- FAX (502) 564-6533

- LOUISIANA
- Chronic Disease Control Program
- Louisiana Department of Health and Hospitals
- 325 Loyola Ave., Rm. 414
- New Orleans, LA 70112
- Telephone (504) 568-7210
- FAX (504) 568-2543

- MAINE
- ASSIST Project
- Division of Health Promotion and Education
- Maine Department of Human Services
- 151 Capitol St.
- State House Station 11
- Augusta, ME 04333
- Telephone (207) 287-5180
- FAX (207) 287-4631

- MARIANA ISLANDS
- Psychiatric Clinical Coordinator
- Department of Public Health and Environmental Services
- P.O. Box 409 CK
- Saipan, MP 96950
- Telephone 670-234-8950, ext. 2500
- FAX 670-234-8930

- MARSHALL ISLANDS
- Director of Human Services
- Alcohol and Substance Abuse
- Ministry of Health and Environment
- P.O. Box 16
- Majuro, Republic of the Marshall Islands 96960
- Telephone 011-692-625-3249
- FAX 011-692-625-3432

- MARYLAND
- Division of Health Education
- Department of Health and Mental Hygiene
- 201 W. Preston St.
- Baltimore, MD 21201
- Telephone (410) 225-1362
- FAX (410) 333-7903

- MASSACHUSETTS
- Office for Nonsmoking and Health
- Massachusetts Department of Public Health
- 250 Washington St., 4th Fl.
- Boston, MA 02108
- Telephone (617) 624-5900
- FAX (617) 624-5922

- MICHIGAN
- ASSIST Project Director
- Chief, Tobacco Section
- Michigan Department of Public Health
- 3423 N. Logan St.
- P.O. Box 30195 - CHP
- Lansing, MI 48909
- Telephone (517) 335-8380
- FAX (517) 335-9648
- Federal Express Address:
- Drop P.O. Box

- MICRONESIA
- Secretary, Department of Health
- FSM National Government
- Palikir Station, PS 70
- Palikir, Pohnpei FSM 96941
- Telephone 011-691-320-2619
- FAX 011-691-320-5263/2785

- MINNESOTA
- ASSIST Project Manager
- Minnesota Department of Health
- 717 Delaware St., S.E.
- P.O. Box 9441
- Minneapolis, MN 55440-9441
- Telephone (612) 623-5623
- FAX (612) 623-5775

- MISSISSIPPI
- Coordinator
- Tobacco Prevention
- Mississippi State Department of Health
- P.O. Box 1700
- Jackson, MS 39215-1700
- Telephone (601) 960-7828
- FAX (601) 354-6278
- Federal Express Address:
- 2423 N. State St.
- Jackson, MS 39216

- MISSOURI
- Project Manager, ASSIST
- Tobacco Control Coordinator
- Missouri Department of Health
- 101 Park DeVille Dr.
- Columbia, MO 65203
- Telephone (314) 876-3260
- FAX (573) 446-8777

- MONTANA
- Health Services Manager
- Department of Health and Environmental Sciences
- 1400 Broadway
- Cogswell Bldg., Rm. C314
- Helena, MT 59620
- Telephone (406) 444-4488
- FAX (406) 444-2606

- NEBRASKA
- Health Promotion and Education
- Nebraska Department of Health
- 301 Centennial Mall South
- P.O. Box 95007
- Lincoln, NE 68509-5007
- Telephone (402) 471-2101
- FAX (402) 471-6446
- Federal Express Address:
- Drop P.O. Box

- NEVADA
- Tobacco Control Coordinator
- Nevada Department of Human Resources
- 505 E. King St., Rm. 304
- Carson City, NV 89710
- Telephone (702) 687-4800
- FAX (702) 687-4988

- NEW HAMPSHIRE
- Bureau of Health Promotion
- New Hampshire Division of Public Health Services
- Health and Welfare Bldg.
- 6 Hazen Dr.
- Concord, NH 03301-6527
- Telephone (603) 271-6892
- FAX (603) 271-6116

- NEW JERSEY
- Coordinator
- ASSIST Project--Tobacco Program
- New Jersey Department of Health
- CN 362, 129 Hanover St.
- Trenton, NJ 08625-0369
- Telephone (609) 984-1310
- FAX (609) 292-3816

- NEW MEXICO
- Program Manager
- Tobacco Use Prevention/ASSIST
- 2329 Wisconsin, N.E., Suite A
- Albuquerque, NM 87110
- Telephone (505) 841-8335
- FAX (505) 841-8333

- NEW YORK
- Program Manager
- Tobacco Control Program, ASSIST Project
- New York State Department of Health
- Corning Tower Bldg.
- Empire State Plaza, Rm. 515
- Albany, NY 12237-0620
- Telephone (518) 474-1515
- FAX (518) 473-2853

- NORTH CAROLINA
- Manager
- Division of Adult Health, ASSIST Project
- North Carolina Department of Environment, Health, and Natural Resources
- P.O. Box 27687
- Raleigh, NC 27611-7687
- Telephone (919) 733-1676
- FAX (919) 733-0488

- Federal Express Address:
- 1330 St. Mary's St.
- Raleigh, NC 27611-7687

- NORTH DAKOTA
- Coordinator
- Tobacco Prevention and Control Program
- 600 E. Boulevard Ave., Judicial Wing, 2nd Fl.
- Bismarck, ND 58505-0200
- Telephone (701)328-3138
- FAX (701) 328-1412

- OHIO
- Chief
- Bureau of Chronic Diseases, Prevention Branch
- Ohio Department of Health
- 246 N. High St.
- P.O. Box 118
- Columbus, OH 43266-0118
- Telephone (614) 466-2144
- FAX (614) 644-7740
- Federal Express Address:
- Drop P.O. Box

- OKLAHOMA
- Health Information Section
- Oklahoma State Department of Health
- 1000 N.E. 10th St.
- Oklahoma City, OK 73117-1299
- Telephone (405) 271-5601
- FAX (405) 271-2865

- OREGON
- Chronic Disease
- Oregon Department of Human Resources
- 800 N.E. Oregon St.
- Portland, OR 97232
- Telephone (503) 731-4025
- FAX (503) 731-4082

- PENNSYLVANIA
- Director
- Tobacco and Control Program
- Pennsylvania Department of Health
- P.O. Box 90, Rm. 1003
- Harrisburg, PA 17108
- Telephone (717) 783-5900
- FAX (717) 783-5498
- Federal Express Address:
- Tobacco Control Program
- Health and Welfare Bldg., Rm. 1003
- Commonwealth Ave. and Forster St.
- Harrisburg, PA 17120

- PALAU
- Minister of Health
- Ministry of Health
- P.O. Box 6027
- Koror, Republic of Palau 96940
- Telephone 011-680-488-2813
- FAX 011-680-488-1725

- PUERTO RICO
- SAMPSF, Preventive Medicine
- Puerto Rico Department of Health
- P.O. Box 70184
- San Juan, PR 00936
- Telephone (809) 274-5645
- FAX (809) 274-7863

- RHODE ISLAND
- ASSIST Project
- Rhode Island Department of Health
- Cannon Bldg., 3 Capitol Hill, Rm. 103
- Providence, RI 02908-5097
- Telephone (401) 277-3329
- FAX (401) 861-5751

- SAMOA
- Associate Director, Public Health Nursing
- Department of Health
- Pago Pago, American Samoa 96799
- Telephone 011-684-4606/5318
- FAX 011-684-633-5379

- SOUTH CAROLINA
- ASSIST Project, Center for Health Promotion
- South Carolina Department of Health and Environmental Control
- 2600 Bull St.
- Columbia, SC 29201
- Telephone (803) 734-4446
- FAX (803) 253-4001

- SOUTH DAKOTA
- Department of Human Services
- Division of Alcohol and Drugs
- 300 E. Hwy. 34
- Hillsview Plaza
- Pierre, SD 57501
- Telephone (605) 773-3123
- FAX (605) 773-5483

- TENNESSEE
- Tennessee Department of Health
- Health Promotion/Disease Control
- Tennessee Tower Bldg., 13th Floor
- 312 8th Ave., N.
- Nashville, TN 37247-5201
- Telephone (615) 741-7366
- FAX (615) 532-8478

- TEXAS
- Office of Smoking and Health
- Texas Department of Health
- 1100 W. 49th St.
- Austin, TX 78756-3199
- Telephone (512) 458-7402
- FAX (512) 458-7618

- UTAH
- Statewide Risk Reduction
- Utah Department of Health
- 288 N. 1460, W.
- Salt Lake City, UT 84116-0660
- Telephone (801) 538-6270
- FAX (801) 538-6036

- VERMONT
- Tobacco Control Coordinator
- Health Promotion/Epidemiology Division
- Vermont Department of Health
- P.O. Box 70
- Burlington, VT 05402
- Telephone (802) 865-7783
- FAX (802) 863-7425

- VIRGIN ISLANDS
- Virgin Islands Department of Social and Health Services
- Charles Harword Complex, Rm. E-25
- Christiansted, St. Croix, VI 00820
- Telephone (809)774-7700
- FAX (809)774-4701

- VIRGINIA
- Virginia Department of Health
- 1500 E. Main St.
- P.O. Box 2448, Suite 245
- Richmond, VA 23218-2448
- Telephone (804) 786-3551
- FAX (804) 371-6152

- WASHINGTON
- ASSIST Project, Heart Disease and Cancer Prevention
- Department of Social and Health Services
- Airdustrial Park, 10, P.O. Box 47835
- Olympia, WA 98504-7835
- Telephone (206) 586-6082
- FAX (206) 664-8779
- Federal Express Address:
- Drop P.O. Box

- WEST VIRGINIA
- Program Manager
- ASSIST Project
- West Virginia Department of Health and Human Resources
- 1411 Virginia St., E.
- Charleston, WV 25301
- Telephone (304) 558-0644
- FAX (304) 558-1553

- WISCONSIN
- ASSIST Project
- Wisconsin Division of Health
- 1400 E. Washington Ave., Rm. 240
- Madison, WI 53703-3041
- Telephone (608) 266-8322
- FAX (608) 266-8925

- WYOMING
- Program Manager
- Health Risk Reduction
- Wyoming Department of Health
- Hathaway Bldg, 4th Fl.
- Cheyenne, WY 82002
- Telephone (307) 777-5949
- FAX (307) 777-5402

- ASTHO HEADQUARTERS
- Director, Tobacco Control Projects
- 415 Second St., N.E.
- Suite 200
- Washington, DC 20002
- Telephone (202) 546-5400
- FAX (202) 544-9349