# References

Abrams DB, Orleans CT, Niaura RN, Goldstein MG, Prochaska JO, Velicer W. Treatment issues in smoking cessation: a stepped care approach Tobacco Control 1993 2(suppl):17 34
Abrams DB, Orleans CT, Niaura RN, Goldstein MG, Prochaska JO, Velicer W. Integrating individual and public health perspectives for treatment of tobacco dependence under managed health care: a combined stepped care and matching model. Ann Behav Med. In press.
American Medical Association. American Medical Association guidelines for the diagnosis and treatment of nicotine dependence: how to help patients stop smoking, Washington (DC): American Medical Association, 1994
Anda RF, Remington PL, Sienko DG, Davis RM. Are physicians advising smokers to quit? The patient's perspective. JAMA 1987 257(14):1916 9
Anda RF, Williamson DF, Escobedo LG, Mast EE, Giovino GA, Remington PL. Depression and the dynamics of smoking: a national perspective JAMA 1990 264(12):1541 5 2395193
Benowitz NL. Nicotine replacement therapy during pregnancy. JAMA. 1991;22:3174-7. [pmid: 1956108].
Biener L, Abrams DB. The contemplation ladder: validation of a measure of readiness to consider smoking cessation Health Psychol 1991 10(5):360 5 1935872
Brandon SL, Tiffany ST, Baker TB. The process of smoking relapse In: Tims F, Leukfeld C, editors Relapse and recovery in drug abuse. National Institute on Drug Abuse Research Monograph 72, Rockville (MD): National Institute on Drug Abuse, 1986
Brandon TH. Negative affect as motivation to smoke. Curr Directions Psychol Science. 1994;3:33-7.
Breckenridge JS. Smoking by outpatients. Hosp Community Psychiatry. 1990;41:454-5. [pmid: 2332234].
Breslau N. Psychiatric co-morbidity of smoking and nicotine dependence. Behav Genet. 1995;25:95-101. [pmid: 7733862].
Breslau N, Kilbey MM, Andreski P. DSM-III-R nicotine dependence in young adults: prevalence, correlates and associated psychiatric disorders. Addiction. 1994;89:743-54. [pmid: 8069175].
Breslau N, Kilbey NM, Andreski P. Nicotine withdrawal symptoms and psychiatric disorders: findings from an epidemiological study of young adults Am J Psychiatry 1992 149(4):464 9 1554030
Browman GP, Wong G, Hodson I, et al. Influence of cigarette smoking on the efficacy of radiation therapy in head and neck cancer. N Engl J Med. 1993;328:159-63. [pmid: 8417381].
Brownson RC, Jackson-Thompson TJ, Wilkerson JC, Davis JR, Owens NW, Fisher EB. Demographic and socioeconomic differences in beliefs about the health effects of smoking. Am J Public Health. 1992;82:99-103. [pmid: 1536345]. [pmcid: 1694417].
Burling TA, Marshall GD, Seidner AL. Smoking cessation for substance abuse inpatients. J Subst Abuse Treat. 1991;3:269-76.
Centers for Disease Control. Cigarette smoking-attributable mortality and years of potential life lost: United States, 1990. MMWR Morb Mortal Wkly Rep. 1993a;42:645-9. [pmid: 8350857].
Centers for Disease Control. Physician and other health care professional counseling of smokers to quit: United States, 1991. MMWR Morb Mortal Wkly Rep. 1993b;42:854-7. [pmid: 8232167].
Centers for Disease Control. Cigarette smoking among adults: United States, 1993. MMWR Morb Mortal Wkly Rep. 1994;43:925-30. [pmid: 7990796].
Centers for Disease Control. Trends in smoking initiation among adolescents and young adults: United States, 1980-1989 MMWR Morb Mortal Wkly Rep 1995 44(28):521 5 7603427
Centers for Disease Control. Cigarette smoking among blacks and other minority populations MMWR Morb Mortal Wkly Rep 1987 36(25):
Cepeda-Benito A. A meta-analytic meta-analytical review of the efficacy of nicotine chewing gum in smoking treatment programs. J Consult Clin Psychol. 1993;61:822-30. [pmid: 8245279].
Cohen SJ, Stookey GK, Katz BP, Drook CA, Christen AG. Helping smokers quit: a randomized controlled trial with private practice dentists. J Am Dent Assoc. 1989;118:41-5. [pmid: 2913103].
Coultas DB, Gong H, Grad R, Handler A, McCurdy SA, Player R, Rhoades ER, Samet JM, Thomas A, Westley M. Respiratory diseases in minorities of the United States. Am J Respir Crit Care Med. 1994;149. [pmid: 8118656].
Cox JL, McKenna JP. Nicotine gum: does providing it free in a smoking cessation program alter success rates? J Fam Pract 1990 31(3):278 80 2391458
Cummings KM, Giovino G, Sciandra R, Koenigsberg M, Emont. Physician advice to quit smoking: who gets it and who doesn't Am J Prev Med 1987 3(2):69 75 3452345
Cummings SR, Rubin SM, Oster G. The cost-effectiveness of counseling smokers to quit JAMA 1989 261(1):75 9 2491762
Curry S. Self-help interventions for smoking cessation. J Consult Clin Psychol. 1993;61:790-803. [pmid: 8245276].
Curry S, Wagner EH, Grothaus LC. Instrinsic and extrinsic motivation for smoking cessation. J Consult Clin Psychol. 1990;58:310-16. [pmid: 2195084].
DerSimonian R, Laird N. Meta analysis in clinical trials. Control Clin Trials. 1986;7:177-88. [pmid: 3802833].
Dix Smith M, McGhan WF, Lauger G. Pharmacist counseling and outcomes of smoking cessation Am Pharm 1995 NS35(8):20 3 2
Eddy DM. The economics of cancer prevention and detection: getting more for less Cancer 1981 47(suppl):1200 9 6786726
Eddy DM. Setting priorities for cancer control programs. J Natl Cancer Inst. 1986;76:187-99. [pmid: 3080634].
Eddy DM. David Eddy ranks the tests. Harv Health Let. 1992;11.
Eddy DM, Hasselblad V. FAST*PRO software for meta-analysis by the confidence profile method [manual for software], San Diego (CA): Academic Press, 1992
Emont SC, Cummings KM. Weight gain following smoking cessation: a possible role for nicotine replacement in weight management. Addict Behav. 1987;12:151-5. [pmid: 3630801].
Fiore MC, Baker TB. Smoking cessation treatment and the good doctor club [editorial] Am J Public Health 1995 85(2):161 3 7856771 1615314
Fiore MC, Epps RP, Manley MW. Missed opportunity: teaching A missed opportunity. Teaching medical students about tobacco cessation and prevention JAMA 1994 271(8):624 6 8301797
Fiore MC, Jorenby DE, Schensky AE, Smith SS, Bauer RR, Baker TB. Smoking status as the new vital sign: effect on assessment and intervention in patients who smoke. Mayo Clin Proc. 1995;70:209-13. [pmid: 7861807].
Fiore MC, Novotny TE, Pierce JP, Giovino GA, Hatziandreu EJ, Newcomb PA, Surawicz TS, Davis RM. Methods used to quit smoking in the United States: do cessation programs help?. JAMA. 1990;263:2760-5. [pmid: 2271019].
Fiore MC, Pierce JP, Remington PL, Fiore BJ. Cigarette smoking: the clinician's role in cessation, prevention, and public health Disease-a-Month 1990 35(4).
Fiore MC, Smith SS, Jorenby DE, Baker TB. The effectiveness of the nicotine patch for smoking cessation: a meta-analysis. JAMA. 1994;271:1940-7. [pmid: 8201739].
Frank E, Winkleby MA, Altman DG, Rockhill B, Fortmann SP. Predictors of physicians' smoking cessation advice. JAMA. 1991;266:3139-44. [pmid: 1956100].
Gelb BD. Preventive medicine and employee productivity Harv Bus Rev 1985 64(2):12 6 10270194
Gilchrist V, Miller RS, Gillanders WR, Scheid DC, Logue EE, Iverson DC, Oprandi AM, Weldy DL, Krell MA. Does family practice at residency teaching sites reflect community practice?. J Fam Pract. 1993;37:555-63. [pmid: 8245806].
Glassman AH. Cigarette smoking: implications for psychiatric illness. Am J Psychiatry. 1993;150:546-53. [pmid: 8465868].
Glassman AH, Covey LS, Dalack GW, Stetner F, Rivelli SK, Fleiss J, Cooper TB. Smoking cessation, clonidine, and vulnerability to nicotine among dependent smokers. Clin Pharmacol Ther. 1993;54:670-9. [pmid: 8275622].
Glassman AH, Helzer JE, Covey LS, Gottler LB, Stetner F, Tipp JE, Johnson J. Smoking, smoking cessation, and major depression JAMA 1990 264(12):1546 9 2395194
Glassman AH, Stetnes F, Stetner F, Walsh BT, Raizman PS, Fleiss JL, Cooper TB, Covey LS. Heavy smokers, smoking cessation, and clonidine: results of a double-blind, randomized trial. JAMA. 1988;259:2863-6. [pmid: 3367452].
Glover ED, Glover PN. The smokeless tobacco problem: risk groups in North America In: Smokeless tobacco or health: an international perspective. Smoking and tobacco control monograph No. 2US Department of Health and Human Services, Public Health Service, National Institutes of Health. Publication No. 92-3461. 1992
Glynn TJ, Manley MW. How to help your patients stop smoking: a National Cancer Institute manual for physicians, Bethesda (MD): US Department of Health and Human Services, Public Health Service, National Institutes of Health, National Cancer Institute. NIH Publication No. 90-3064,1990
Gourlay S. The pros and cons of transdermal nicotine therapy. Med J Aust. 1994;160:152-9. [pmid: 8295585].
Green DE. Teenage smoking: immediate and long-term patterns, Washington (DC):National Institute of Education,1979
Gritz ER, Klesges RC, Meyers AW. The smoking and body weight relationship: implications for intervention and postcessation weight control. Ann Behav Med. 1989;11:144-53.
Gross J, Stitzer ML, Maldonado J. Nicotine replacement: effects on postcessation weight gain. J Consult Clin Psychol. 1989;57:87-92. [pmid: 2925978].
Group Health Association of America. HMO industry profile: 1993 edition, Washington (DC): Group Health Association of America, 1993
Hajek P, Jackson P, Belcher M. gain.]. JAMA. 1988;260:2593-6. [pmid: 3172445].
Hall SM, Munoz RF, Reus VI, Sees KL. Nicotine, negative affect and depression. J Consult Clin Psychol. 1993;61:761-7. [pmid: 7902368].
Hall SM, Munoz RF, Reus VI. Cognitive-behavioral intervention increases abstinence rates for depressive-history smokers. J Consult Clin Psychol. 1994;62:141-6. [pmid: 8034816].
Hall SM, Tunstall CD, Rugg D, Jones RT, Benowitz N. Nicotine gum and behavioral treatment in smoking cessation. J Consult Clin Psychol. 1985;53:256-8. [pmid: 3998252].
Hall SM, Tunstall CD, Vila KL, Duffy J. Weight gain prevention and smoking cessation: cautionary findings. Am J Public Health. 1992;82:799-803. [pmid: 1585959]. [pmcid: 1694191].
Hartmann N, Jarvik M, Wilkins J. Reduction of cigarette smoking by the use of a nicotine patch. Arch Gen Psychiatry. 1989;46.
Hartmann N, Leong GB, Glynn SM, Wilkins JN, Jarvik ME. Transdermal nicotine and smoking behavior in psychiatric patients. Am J Psychiatry. 1991;148:374-5. [pmid: 1992843].
Hatsukami D, LaBounty L, Hughes J, Laine D. Effects of tobacco abstinence on food intake among cigarette smokers. Health Psychol. 1993;12:499-502. [pmid: 8293734].
Hatziandreu EJ, Pierce JP, Lefkopoulou M, Fiore MC, Mills SL, Novotny TE, Giovano GA, Davis RM. Quitting smoking in the United States in 1986 J Natl Cancer Inst 1990 82(17):1402 6 2388290
Hayward RA, Meetz HK, Shapiro MF, Freeman DE. Utilization of dental services: 1986 patterns and trends J Public Health Dent 1989 49(3):147 52 2769632
Heatherton TF, Kozlowski LT, Frecker RC, Fagerstrom K-O. The Fagerstrom Test for Nicotine Dependence: a revision of the Fagerstrom Tolerance Questionnaire Br J Addiction 1991 86(9):11 19 27
Henningfield JE. Nicotine medications for smoking cessation. N Engl J Med. 1995;333:1196-203. [pmid: 7565976].
Henry RC, Ogle KS, Snellman LA. Preventive medicine: physician practices, beliefs, and perceived barriers for implementation Fam Med 1987 19(2):110 3 3596091
Herdman R, Hewitt M, Laschober M. Smoking-related deaths and financial costs: Office of Technology Assessment estimates for 1990Congress of the United States, Office of Technology Assessment, 1993
Hjalmarson A, Franzon M, Westin A, Wiklund O. Effect of nicotine nasal spray on smoking cessation: a randomized, placebo-controlled, double-blind study. Arch Intern Med. 1994;154:2567-72. [pmid: 7979853].
Hofstetter A, Schutz Y, Jequier E, Wahren J. Increased 24-hour energy expenditure in cigarette smokers. N Engl J Med. 1986;314:79-82. [pmid: 3941694].
Hollis JF, Lichtenstein E, Vogt TM, Stevens VJ, Biglan A. Nurse-assisted counseling for smokers in primary care. Ann Intern Med. 1993;118:521-5. [pmid: 8442622].
Hosmer DW, Lemeshow S. Applied logistic regression, New York: Wiley, 1989
Hughes JR. Possible effects of smoke-free inpatient units on psychiatric diagnosis and treatment. J Clin Psychiatry. 1993;54:109-14. [pmid: 8468309].
Hughes JR, Frances RJ. How to help psychiatric patients stop smoking. Psychiatr Serv. 1995;46:435-45. [pmid: 7627666].
Hughes JR, Wadland WC, Fenwick JW, Lewis J, Bickel WK. Effect of cost on the self-administration and efficacy of nicotine gum: a preliminary study. Prev Med. 1991;20:186-496.
Hurt RD, Dale LC, Offord KP, Bruce BK, McClain FL, Eberman KM. Inpatient treatment of severe nicotine dependence. Mayo Clin Proc. 1992;67:823-8. [pmid: 1434925].
Hurt RD, Eberman KM, Croghan IT, Offord KP, Davis LJ Jr, Morse RM, Palmer MA, Bruce BK. Nicotine dependence treatment for patients undergoing during inpatient treatment for other addictive disorders addictions: a prospective intervention trial Alcohol Clin Exp Res 1994 18(4):867 72 7978097
Hurt RD, Eberman KM, Slade J, Karan L. Treating nicotine addiction in patients with other addictive disorders. : Nicotine addiction: principles and management In Orleans CT, Slade J, editors, New York: Oxford, 1993 310 26
Hurt RD, Lauger GG, Offord KP, Bruce BK, Dale LC. An integrated approach to the treatment of nicotine dependence in a medical center setting Clin Res 1991 39(2):
Jaen CR, Stange KC, Nutting PA. Competing demands of primary care: a model for the delivery of clinical preventive services. J Fam Pract. 1994;38:166-71. [pmid: 8308509].
Johnson RE, Hollis JF, Stevens VJ, Woodson GT. Patterns of nicotine gum use in a health maintenance organization. DICP Ann Pharmacother. 1991;25:730-5.
Johnston LD, O'Malley PM, Bachman JG. National survey results on drug use from monitoring the future study, 1975-1994: vol. 1, secondary school students. Bethesda (MD)US Department of Health and Human Services, Public Health Service, National Institutes of Health, National Institute on Drug Abuse. NIH Publication No. 95-4026, 1995
Jones RM. Smoking before surgery: the case for stopping. Br Med J. 1985;290:1763-4. [pmid: 3924243]. [pmcid: 1415970].
Kenford SL, Fiore MC, Jorenby DE, Smith SS, Wetter D, Baker TB. Predicting smoking cessation: who will quit with and without the nicotine patch. JAMA. 1994;271:589-94. [pmid: 8301790].
Klesges RC, Klesges LM. Cigarette smoking as a dietary strategy in a university population. Int J Eat Disord. 1988;7:413-9.
Klesges RC, Meyers AW, Klesges LM, LaVasque ME. Smoking, body weight, and their effects on smoking behavior: a comprehensive review of the literature. Psychol Bull. 1989;106:204-30. [pmid: 2678202].
Klesges RC, Shumaker SA, editors. Proceedings of the national working conference on smoking and body weight Health Psychol 1992 11(suppl):1 22 1396497
Kottke TE, Solberg LI. Is it not time to make smoking a vital sign?. Mayo Clin Proc. 1995;70:303-4. [pmid: 7861820].
Kottke TE, Solberg LI, Brekke ML. Beyond efficacy testing: introducing preventive cardiology into primary care Am J Prev Med 1990 6(suppl 1):77 83 2200453
Kottke TE, Solberg LI, Brekke ML, Conn SA, Maxwell P, Brekke MJ. A controlled trial to integrate smoking cessation advice into primary care practice: doctors helping smokers, round III. J Fam Pract. 1992;34:701-8. [pmid: 1593243].
Lam W, Sze PC, Sacks HS, Chalmers TC. Meta-analysis of randomized controlled trials of nicotine gum. Lancet. 1987;2:27-30. [pmid: 2885512].
Lichtenstein E, Hollis JF. Patient referral to a smoking cessation program: who follows through?. J Fam Pract. 1992;34:739-44. [pmid: 1593248].
Logsdon DN, Lazaro CM, Meier RV. The feasibility of behavioral risk reduction in primary medical care. Am J Prev Med. 1989;5. [pmid: 2789846].
Lynch BS, Bonnie RJ, editors.Institute of Medicine Committee on Preventing Nicotine Addiction in Children and Youths. Growing up tobacco free: preventing nicotine addiction in children and youths, Washington (DC): Natl Acad Press, 1994
Marcus AC, Crane LA, Shopland DR, Lynn WR. Use of smokeless tobacco in the United States: recent estimates from the current population survey. Monogr Natl Cancer Inst. 1989;8:17-24.
Mecklenburg RE, Christen AG, Gerbert B, Gift MC, et al. How to help your patients stop using tobacco: a National Cancer Institute manual for the oral health team 1990US DHHS Public Health Service, National Institutes of Health, National Cancer Institute. NIH Publication No. 91-3191, 1991
Moffatt RS, Owens SG. Cessation from cigarette smoking: changes in body weight, body composition, resting metabolism, and energy consumption. Metabolism. 1991;40:465-70. [pmid: 2023532].
Moss AJ, Allen KF, Giovino GA, Mills SL. Recent trends in adolescent smoking, smoking-uptake correlates, and expectations about the future: advance data from Vital and Health Statistics, No. 221, Hyattsville (MD): National Center for Health Statistics, 1992
[Dolan-]Mullen PD, Ramirez G, Groff JY. A meta-analysis of randomized trials of prenatal smoking cessation interventions. Am J Obstet Gynecol. 1994;171:1328-34. [pmid: 7977542].
Multiple Risk Factor Intervention Trial Research Group. Mortality rates after 10.5 years for participants in the Multiple Risk Factor Intervention Trial. JAMA. 1990;263:1795-1801. [pmid: 2179590].
National Cancer Institute. Tobacco and the clinician: interventions for medical and dental practiceNIH Publication No. 94-3693. Monogr Natl Cancer Inst 1994 5:1-22
National Heart, Lung, and Blood Institute. How you can stop patients from smoking, Bethesda, MD: US Department of Health and Human Services, Public Health Service, National Institutes of Health, National Heart, Lung, and Blood Institute. NIH Publication No. 91-2961, 1991.
Nelson DE, Emont SL, Brackbill RM, Cameron LL, Peddicord J, Fiore MC. Cigarette smoking prevalence by occupation in the United States J [Occup] Med 1994 36(5):516 25 8027876
Nides M, Rand C, Dolce J, Murray R, O'Hara P, Voelker H, Connett J. Weight gain as a function of smoking cessation and 2-mg nicotine gum use among middle-aged smokers with mild lung impairment in the first 2 years of the lung health study. Health Psychol. 1994;13:354-61. [pmid: 7957014].
Noppa H, Bengtsson C. Obesity in relation to smoking: a population study of women in Goteborg, Sweden. Prev Med. 1980;9:534-43. [pmid: 7403022].
Ockene JK. Smoking intervention: the expanding role of the physician. Am J Public Health. 1987;77:782-3. [pmid: 3592029]. [pmcid: 1647191].
Ockene JK, Kristeller J, Goldberg R, Amick TL, Pekow PS, Hosmer D, Quirk M, Kalan K. Increasing the efficacy of physician-delivered interventions: a randomized clinical trial. J Gen Intern Med. 1991;6:1-8. [pmid: 1999742].
Orleans CT. Treating nicotine dependence in medical settings: a stepped-care model In: Orleans CT, Slade J, editors. Nicotine addiction: principles and management, New York: Oxford University Press. , 1993 :145-61
Orleans CT, Shoenbach VJ, Salmon MA, Strecher VJ, Kalsbeek W, Quade D, Brooks EF, Konrad TR, Blackmon C, Watts CD. A survey of smoking and quitting patterns among black Americans. Am J Public Health. 1989;79:176-81. [pmid: 2913836]. [pmcid: 1349929].
Orleans CT, George LK, Houpt JL, Brodie KH. Health promotion in primary care: a survey of US family practitioners. Prev Med. 1985;14:636-47. [pmid: 4070193].
Oster G, Huse DM, Delea TE, Colditz MB. Cost-effectiveness of nicotine gum as an adjunct to physician's advice against cigarette smoking. JAMA. 1986;256:1315-8. [pmid: 3091857].
Pederson LL. Compliance with physician advice to quit smoking: a review of the literature. Prev Med. 1982;11:71-84. [pmid: 7079248].
Perkins KA. Issues in the prevention of weight gain after smoking cessation. Ann Behav Med. 1994;16:46-52.
Pirie PL, McBride CM, Hellerstedt W, Jeffery RW, Hatsukami D, Allen S, Lando H. Smoking cessation in women concerned about weight. Am J Public Health. 1992;82:1238-43. [pmid: 1503165]. [pmcid: 1694323].
Po ALW. Li Wan Po A. Transdermal nicotine in smoking cessation: a meta-analysis. Eur J Clin Pharmacol. 1993;45:519-28. [pmid: 8157037].
Prochaska JO, Goldstein MG. Process of smoking cessation: implications for clinicians Clin Chest Med 1991 42(4):727 75 1747990
Resnick, MP. Treating nicotine addiction in patients with psychiatric comorbidity In: Orleans CT, Slade J, editors. Nicotine addiction: principles and management, New York: Oxford University Press, 1993 327-36
Robinson MD, Laurent SL, Little JM Jr. Including smoking status as a new vital sign: it works J Fam Pract 1995 40(6):556 63 7775909
Royce JM, Hymowitz N, Corbett K, Hartwell TD, Orlandi MA. Smoking cessation factors among African Americans and whites. COMMIT Research Group Am J Public Health 1993 83(2):220 6 8427327 1694582
Russell MAH, Wilson C, Taylor C, Baker CD. Effect of general practitioners' advice against smoking. Br Med J. 1979;2:231-5. [pmid: 476401]. [pmcid: 1595592].
Schwid SR, Hirvonen MD, Keesey RE. Nicotine effects on body weight: a regulatory perspective. Am J Clin Nutr. 1992;55:878-84. [pmid: 1550071].
Scott CS, Neighbor WE. Preventive care attitudes of medical students. Soc Sci Med. 1985;21:299-306. [pmid: 4035418].
Silagy C, Mant D, Fowler G, Lodge M. Meta-analysis on efficacy of nicotine replacement therapies in smoking cessation. Lancet. 1994;343:139-42. [pmid: 7904003].
Stamford BA, Matter S, Fell RD, Papanek P. Effects of smoking cessation on weight gain, metabolic rate, caloric consumption, and blood lipids. Am J Clin Nutr. 1986;43:486-94. [pmid: 3962901].
Stevens VJ, Glasgow RE, Hollis JF, Lichtenstein E, Vogt TM. A smoking- cessation intervention for hospital patients Med Care 1993 31(1):65 72 8417271
Stotts RC, Glynn TJ, Baquet CR. Smoking cessation among blacks. J Health Care Poor Underserved. 1991;2. [pmid: 1777542].
Strecher VJ, Kreuter M, Den Boer DJ, Kobrin S, Hospers HJ, Skinner CS. The effects of computer-tailored smoking cessation messages in family practice settings J Fam Pract 1994 39(3):262 70 8077905
Sugarman JR, Warren CW, Oge L, Helgerson SD. Using the Behavioral Risk Factor Surveillance System to monitor year 2000 objectives among American Indians. Pub Health Rep. 1992;107:449-56. [pmid: 1641442]. [pmcid: 1403676].
Sutherland G, Stapleton JA, Russell MAH, Jarvis MJ, Hajek P, Belcher M, Fegerabend C. Randomized controlled trial of nasal nicotine spray in smoking cessation. Lancet. 1992;340:324-9. [pmid: 1353803].
Tang JL, Law M, Wald N. How effective is nicotine replacement therapy in helping people to stop smoking?. Br Med J. 1994;308:21-6. [pmid: 8179658].
Tomar SL, Husten CG, Manley M. Do dentists and physicians advise tobacco users to quit?. J Am Dent Assoc. 1996;127:259-65. [pmid: 8682997].
Tonnesen P, Norregaard J, Mikkelsen K, Jorgensen S, Nilsson F. A double-blind trial of a nicotine inhaler for smoking cessation. JAMA. 1993;269:1268-71. [pmid: 8437304].
US Department of Health and Human Services. Healthy People 2000, midcourse review and 1995 revisions, Washington (DC): US Department of Health and Human Services, Public Health Service, 1995. 7594315
US Department of Health and Human Services. Healthy People 2000: national health promotion and disease prevention objectives, Washington (DC): US Department of Health and Human Services, Public Health Service. DHHS Publication No. (PHS) 91-50212, 1991
US Department of Health and Human Services. Preventing tobacco use among young people: a report of the Surgeon General, Atlanta (GA): US Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1994
US Department of Health and Human Services. Reducing the health consequences of smoking: 25 years of progress. A report of the Surgeon General, Atlanta (GA): US Department of Health and Human Services, Public Health Service, Centers for Disease Control, Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. DHHS Publication No. (PHS) (CDC) 89-8411, 1989 2560528
US Department of Health and Human Services. The health benefits of smoking cessation: a report of the Surgeon General, Atlanta (GA): US Department of Health and Human Services, Public Health Service, Centers for Disease Control, Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. DHHS Publication No. (CDC) 90-8416, 1990
US Department of Health and Human Services. The health consequences of smoking: nicotine addiction. A report of the Surgeon General, Atlanta (GA): US Department of Health and Human Services, Public Health Service, Centers for Disease Control, Center for Chronic Disease Prevention and Health Promotion, Office of Smoking and Health. DHHS Publication No. (PHS) (CDC) 88-8406, 1988 2855251
Wechsler H, Levine S, Idelson RK, Rohman M, Taylor JO. The physician's role in health promotion. [A survey of primary-care practitioners.]. N Engl J Med. 1983;308:97-100. [pmid: 6847940].
Wewers ME, Bowen JM, Stanislaw AE, Desimone VB. A nurse-delivered smoking cessation intervention among hospitalized postoperative patients--influence of a smoking-related diagnosis: a pilot study Heart Lung 1994 23(2):151 6 8206773
Williamson DF, Madans J, Anda RF, Kleinman JC, Giovino GA, Beyers T. Smoking cessation and severity of weight gain in a national cohort. N Engl J Med. 1991;324:739-45. [pmid: 1997840].
Zelman DC, Brandon TH, Jorenby DE, Baker TB. Measures of affect and nicotine dependence predict differential response to smoking cessation treatments. J Consult Clin Psychol. 1992;60:943-52. [pmid: 1460156].
Zhu SH, Stretch V, Balabanis M, Rosbrook B, Sadler G, Pierce JP. Telephone counseling for smoking cessation: effects of a single-session and multiple-session interventions. J Consult Clin Psychol. 1996;64:1-10.