# Executive Summary

Smoking cessation interventions offer clinicians and health care providers their greatest opportunity to improve the current and future health of all Americans (U.S. Department of Health and Human Services [DHHS], 1989). It is essential, therefore, that clinicians, smoking cessation specialists, health care administrators, and health care purchasers take an active role in reducing the prevalence of tobacco use. One way to do this is through the support and delivery of effective smoking cessation interventions.

This guideline is a product of the Smoking Cessation Guideline Panel (the "panel"), which was charged by AHCPR to identify effective, experimentally validated smoking cessation treatments and practices. Through a systematic and exhaustive review and analysis of the available scientific research literature, the panel developed practice recommendations that address three principal audiences: the broad range of primary care clinicians, for whom smoking cessation is just one of many clinical activities; smoking cessation specialists, for whom smoking cessation treatment is a major professional activity; and health care administrators/insurers/purchasers. The last group can influence smoking cessation by supporting the implementation and reimbursement of effective cessation activities. Major findings and recommendations of this guideline can be summarized in six points:

1. Effective smoking cessation treatments are available, and every patient who smokes should be offered one or more of these treatments.
2. It is essential that clinicians determine and document the tobacco-use status of every patient treated in a health care setting.
3. Brief cessation treatments are effective, and at least a minimal intervention should be provided to every patient who uses tobacco.
4. A dose-response relation exists between the intensity and duration of a treatment and its effectiveness. In general, the more intense the treatment, the more effective it is in producing long-term abstinence from tobacco.
5. Three treatment elements, in particular, are effective, and one or more of these elements should be included in smoking cessation treatment: (1) nicotine replacement therapy (nicotine patches or gum), (2) social support (clinician-provided encouragement and assistance), and (3) skills training/problem solving (techniques on achieving and maintaining abstinence).
6. Effective reduction of tobacco use requires that health care systems make institutional changes that result in systematic identification of, and intervention with, all tobacco users at every visit.

The vast majority of data available to the panel came from studies of interventions with smokers. Therefore, in most sections of the guideline, the panel specifically refers to "smoking" or "smoking cessation." However, panel consensus is that many, if not all, recommendations in this guideline pertain to assessment and treatment of all tobacco users. Therefore, the panel encourages clinicians and other individuals providing cessation services to use these recommendations to guide their treatment of smokeless tobacco users as well as cigar and pipe users.

The six major findings listed above should be important for all three professional target audiences. However, some findings have special relevance to certain audiences, and Chapter 2 of this guideline distills findings for the three audiences. For instance, the smoking cessation specialist is directed to the section entitled Tobacco Cessation Specialists and Programs, where findings regarding the effective constituents of intensive cessation treatments are summarized.

Many guideline findings are highly relevant to primary care and other clinicians. One important finding for this audience is that virtually all types of clinicians -- physicians, nurses, nurse practitioners, dentists, psychologists, pharmacists, respiratory and physical therapists, physician assistants, and many others -- can effectively deliver tobacco cessation treatments (Cohen, Stookey, Katz, et al., 1989; Dix Smith, McGhan, Lauger, 1995; Hall, Tunstall, Rugg, et al., 1985; Hollis, Lichtenstein, Vogt, et al., 1993; National Heart, Lung, and Blood Institute, 1991; Ockene, Kristeller, Goldberg, et al., 1991; Wewers, Bowen, Stanislaw, et al., 1994). Also emphasized is the fact that very brief treatments, such as firm advice to quit smoking, can effectively boost long-term cessation. In addition, clinicians are offered a series of specific steps to follow to intervene effectively with their patients who use tobacco (see the first section in Chapter 2, Primary Care Clinicians).

The attention of health care administrators/insurers/purchasers is directed to the third section of Chapter 2, which highlights the importance of institutional changes that ensure that health care systems identify and intervene with every patient who uses tobacco. This unique emphasis reflects panel recognition of the increasing role of managed care in health care delivery. This recognition requires the guideline to move beyond a traditional focus on the clinician and to address the potential of health care delivery organizations to ensure that tobacco users are reliably identified and treated.

The most significant message of this guideline has great relevance to anyone concerned with health care. This guideline challenges clinicians and others to change the nature of clinical practice to address universally and systematically the leading preventable cause of illness and death in our society (DHHS, 1988; 1989).

Tobacco use has an enormous impact on health in the United States. Approximately 25 percent of adult Americans smoke cigarettes, yet smokers enter and exit the health care system each day without receiving treatment for this important health risk. Clinicians have unique access to individuals who use tobacco -- more than 70 percent of smoking Americans visit a clinician each year. Yet half of these individuals report having never been urged to quit by a clinician, and more than 70 percent now say they want to quit and have made at least one unsuccessful prior quit attempt. American clinicians are missing a unique opportunity to help their patients who use tobacco. This guideline offers a simple and flexible set of strategies that ensure that all patients who use tobacco are offered motivational interventions and effective treatments to overcome this powerful addiction.