# Acknowledgments

Many organizations and individuals made significant contributions during the development of this guideline. Although they are too numerous to mention here, the Contributors section lists individual consultants, peer reviewers, and support staff. This guideline would not have been possible without their collaborative efforts.

All persons, organizations, and agencies with an interest in the smoking cessation guideline were invited to participate at a public meeting held in Bethesda, Maryland, on November 9, 1994. The panel gratefully acknowledges the valuable input received during that session.

The panel gratefully acknowledges the extraordinarily supportive efforts of Ernestine W. Murray, RN, MAS, panel project officer from the Office of the Forum for Quality and Effectiveness in Health Care, Agency for Health Care Policy and Research (AHCPR). We also wish to thank Cheryl Campbell of Technical Resources International, Inc., and Sharon Sokoloff, PhD, of Mikalix and Company for their collaboration and cooperation with this project.

The panel particularly thanks the three key consultants in this project: Timothy Baker, PhD, Senior Scientific Advisor; Victor Hasselblad, PhD, Statistical Methodologist; and David Schriger, MD, MPH, Methodologist.

Finally, the panel extends its gratitude and appreciation to the Wisconsin and Alabama staff members for their tireless efforts in bringing this project to completion. In particular, we thank David Wetter, PhD, Project Director; Connie Kohler, PhD, Project Co-Director; Lisa Wetter, Project Manager; Kathleen Reardon, Project Co-Manager; and Sarah Trost, Project Co-Manager.