# Special Populations and Topics

## Background

Many factors could potentially affect the choice, delivery, and efficacy of cessation interventions. This possibility raises numerous questions. For instance, should interventions be tailored or modified on the basis of gender, age, or hospitalization status? Should pregnant smokers receive nicotine replacement therapy? Do smoking cessation interventions work with smokeless tobacco users? How do cessation and intervention affect weight, and should treatment be modified with those effects in mind? These special issues are considered in this chapter. It is important to note that many health care specialties can have a key role in addressing these issues (e.g., obstetrics and family practice for pregnant smokers; gynecology and family practice for preconceptional counseling and general health maintenance; pediatrics for children and adolescents; internal medicine (including cardiology, pulmonology, and oncology) and family practice for hospitalized patients; and dentistry and orthodonture for smokeless tobacco users).

## Gender

Recommendation: The same smoking cessation treatments are effective for both men and women. Therefore, the same interventions can be used with both sexes. (Strength of Evidence = B)

One important question regarding quitting smoking is whether men and women should receive different cessation interventions. Smoking cessation clinical trials reveal that the same treatments benefit both men and women. Moreover, epidemiologic studies do not show a consistent gender difference in quit attempts and success rates. Few studies have examined programs specifically tailored to one gender, however. Although research suggests that women benefit from the same interventions as do men, women may face different stressors and barriers to quitting that may be addressed in treatment. These include greater likelihood of depression, weight control concerns, and issues surrounding child care.

Evidence

There is no consistent evidence of gender differences in response to smoking cessation treatments. (Strength of Evidence = B)

## Racial and Ethnic Minorities

Recommendation: Members of racial and ethnic minorities should be provided smoking cessation treatments shown to be effective in this guideline. (Strength of Evidence = B)

Recommendation: Whenever possible, smoking cessation treatments should be modified or tailored to be appropriate for the ethnic or racial populations with which they are used. (Strength of Evidence = C)

Ethnic and racial minority groups in the United States -- African Americans, American Indians/Native Americans, Alaskan Natives, Asian and Pacific Islanders, Hispanics -- experience higher mortality in a number of disease categories compared with the white majority. For example, African Americans experience substantial excess mortality from cancer, cardiovascular disease, and infant death, all of which are directly affected by tobacco use (CDC, 1987). American Indians and Alaskan Native subgroups have some of the highest documented rates of infant mortality caused by sudden infant death syndrome (Coultas, Gong, Grad, et al., 1994). Therefore, there is a critical need to deliver effective smoking intervention to ethnic and racial minorities.

There are well-documented differences between racial and ethnic minorities and the white majority in smoking patterns and in smoking and quitting prevalence (Orleans, Schoenbach, Salmon, et al., 1989; Stotts, Glynn, and Baquet, 1991). In addition, smoking prevalence and patterns vary substantially among minority subgroups (Coultas, Gong, Grad, et al., 1994). Racial and ethnic minorities also differ from whites in awareness of health effects of smoking (Brownson, Jackson-Thompson, Wilkerson, et al., 1992) and a sense of fatalism that may affect disease prevention efforts. On the other hand, both nicotine addiction and desire to quit appear to be prevalent across all racial and ethnic groups (Orleans, Schoenbach, Salmon, et al., 1989; Royce, Hymowitz, Corbett, et al., 1993; Stotts, Glynn, and Baquet, 1991).

Few studies have examined interventions specifically tailored to particular ethnic or racial groups, and there is no consistent evidence that tailored cessation programs result in higher quit rates in these groups. Moreover, smoking cessation interventions developed for the general population have been effective with racial and ethnic minority participants. Therefore, clinicians who see minority group patients should offer them treatments identified as effective in this guideline. Clinicians should remain sensitive, however, to individual differences and health beliefs that may affect treatment acceptance and success (see section in Chapter 3, Specialized Assessment).

Because of the small amount of research on this topic, there is currently little support for the obligatory tailoring of cessation treatments for minority populations. Logically, however, tailoring may be necessary at times for effective intervention. For instance, cessation counseling or self-help materials must be conveyed in a language understood by the smoker. Additionally, culturally appropriate models or examples may increase the smoker's acceptance of treatment. Certainly, practices with multiethnic or multiracial populations should make culturally appropriate materials available whenever resources permit.

Among subgroups of racial and ethnic minorities, some smoke at exceptionally high rates and suffer high rates of smoking-attributable morbidity and mortality (Coultas, Gong, Grad, et al., 1994; Sugarman, Warren, Oge, at al., 1992). Yet, there is relatively little extant research on optimal interventions or on the specific barriers or impediments to successful cessations for these populations (e.g., relatively low educational attainment, inadequate access to medical care). These are important topics for future research.

Evidence

The following statements support the above recommendations:

- Smoking cessation treatments identified as effective in this guideline increase smoking cessation rates among members of ethnic and racial minorities. (Strength of Evidence = B)
- Smoking is especially prevalent among some racial and ethnic minority subgroups and results in mortality and morbidity. (Strength of Evidence = A)
- Although little research has been done on the effectiveness of treatment tailoring for ethnic and racial minority populations, some types of tailoring such as the use of language-appropriate materials should increase treatment effectiveness. (Strength of Evidence = C)

## Pregnancy

Recommendation: Pregnant smokers should be strongly encouraged to quit throughout pregnancy. Because of the serious risks of smoking to the pregnant smoker and fetus, pregnant smokers should be offered intensive counseling treatment. (Strength of Evidence = A)

Recommendation: Minimal interventions should be used if more intensive interventions are not feasible. (Strength of Evidence = C)

Recommendation: Motivational messages regarding the impact of smoking on both the pregnant smoker and fetus should be given. (Strength of Evidence = C)

Recommendation: Nicotine replacement should be used during pregnancy only if the increased likelihood of smoking cessation, with its potential benefits, outweighs the risk of nicotine replacement and potential concomitant smoking. (Strength of Evidence = C)

Smoking in pregnancy imparts risks to both the woman and the fetus. Many women are motivated to quit during pregnancy, and health care professionals can take advantage of this motivation by reinforcing the notion that cessation will be best for the fetus, with postpartum benefits for both mother and children. On the other hand, clinicians should be aware that some pregnant women may try to hide their smoking status.

Quitting smoking prior to conception or early in the pregnancy is most beneficial, but health benefits result from cessation at any time. Therefore, a pregnant woman who still smokes should continue to be encouraged and helped to quit. Women who quit smoking during pregnancy have a high rate of relapse in the postpartum period. Relapse is common in the postpartum period even among women who have maintained total abstinence from tobacco for 6 or more months during pregnancy. Relapse postpartum may be decreased by continued emphasis on the relationship between maternal smoking and poor health outcomes (sudden infant death syndrome, respiratory infections, asthma, and middle ear disease) in infants and children. General Strategy 9 outlines clinical factors to address when counseling pregnant women about smoking.

No clinical trials have assessed the benefits and risks of nicotine replacement therapy as an aid to smoking cessation in pregnant women. In a review of this topic Benowitz (1991) concluded that, for pregnant women, the benefits of nicotine replacement therapy outweigh the risks of both continued smoking and nicotine replacement itself. Benowitz limited this conclusion, however, to those pregnant women who cannot stop without replacement therapy and suggested that benefits would be the greatest for heavy smokers.

To assess the effectiveness of smoking cessation during pregnancy, the panel used both a published meta-analysis (Mullen, Ramirez, and Groff, 1994) and a meta-analysis conducted by panel staff (Table 18). The meta-analysis conducted by panel staff was based on six studies evaluating the effectiveness of smoking cessation counseling in pregnant smokers. The effectiveness of counseling interventions in these studies was compared with either "no treatment" or "usual care" conditions. The latter usually consisted of a recommendation to stop smoking that was often supplemented by provision of self-help material or referral to a stop-smoking program. Because of the small number of studies available for analysis, only the impact of counseling (greater than 10 minutes of person-to-person contact) was examined in the meta-analysis. Less intense interventions, such as those involving "minimal contact" or "brief counseling" (see subsection in Chapter 3, Intensity of Person-to-Person Clinical Intervention), were not examined because of a lack of relevant studies. Both the panel meta-analysis and the published meta-analysis yielded essentially the same finding -- smoking cessation interventions during pregnancy are effective and should be used to benefit both the woman and the fetus.

Table 18. Efficacy of counseling intervention with pregnant smokers

Level of contact | Number of arms | Estimated odds ratio (95 C.I.) | Estimated cessation rate (95C.I.)
No contact/usual care (reference group) | 11 | 1.0 | 7.9
Counseling | 8 | 2.0 (1.3-2.9) | 14.7 (9.8-19.5)

Evidence

The following statements support the above recommendations:

- A published meta-analysis and a meta-analysis conducted by panel staff (n = 14 studies) suggest that counseling interventions during pregnancy increase quit rates above those of pregnant women who do not receive such interventions. (Strength of Evidence = A)
- Because of the small number of studies examining minimal counseling in pregnant smokers, no focused statistical tests were possible on this topic. However, the panel concluded that minimal counseling has a beneficial effect and should be used if more intensive counseling is not feasible. (Strength of Evidence = C)

## Hospitalized Smokers

Recommendation: For every hospitalized patient, the following steps should be taken: (a) ask each patient on admission if he/she smokes and document smoking status; (b) for current smokers, list smoking status on the admission problem list and as a discharge diagnosis; (c) assist all smokers with quitting during the hospitalization, using treatments identified as effective in this guideline, including nicotine replacement therapy if appropriate; and (d) provide advice and assistance on how to remain abstinent after discharge. (Strength of Evidence = C)

It is vital that hospitalized patients attempt to quit smoking, because smoking may interfere with their recovery. Among cardiac patients, second heart attacks are more common in those who continue to smoke (Multiple Risk Factor Intervention Trial Research Group, 1990). Lung, head, and neck cancer patients who are successfully treated, but who continue to smoke, are at elevated risk for a second cancer (Browman, Wong, Hodson, et al., 1993). Smoking negatively affects bone and wound healing (Jones, 1985).

Every hospital in the United States must now be smoke free if it is to be accredited by the Joint Commission on Accreditation of Healthcare Organizations (JCAHO). As a result, hospitalized patients may be particularly motivated to make a quit attempt for two reasons. First, the illness resulting in hospitalization may have been caused or exacerbated by smoking, highlighting the patient's personal vulnerability to the health risks of smoking. Second, motivation may be enhanced during hospitalization because the smoker is temporarily housed in a smoke-free environment. For these reasons, clinicians should use hospitalization as an opportunity to promote smoking cessation in their patients who smoke (Hurt, Lauger, Offord, et al., 1991; Stevens, Glasgow, Hollis, et al., 1993). Patients in long-term care facilities should also receive cessation interventions identified as efficacious in this guideline.

Specifically, clinicians and hospital administrators should collaborate to ensure that systems are in place that identify the smoking status of all patients admitted to a hospital and that provide at least a brief clinical intervention to every hospitalized patient who smokes.

Finally, smokers may experience nicotine withdrawal symptoms during a hospitalization. Clinicians should consider providing temporary nicotine patch therapy during a hospitalization to reduce such symptoms.

### Efficacy of Inpatient Hospital Smoking Cessation Treatment

Five studies met selection criteria for analyses examining the effectiveness of inpatient hospital smoking cessation treatment compared with usual care. Because of the limited number of studies, no attempt was made to separate the level or type of treatment. Results are shown in Table 19.

Table 19. Efficacy of inpatient smoking cessation treatment (n = 5 studies)

Type of treatment | Number of arms | Estimated odds ratio (95 C.I.) | Estimated cessation rate (95C.I.)
No inpatient smoking cessation treatment (reference group) | 5 | 1.0 | 18.0 (10.1-27.5)
Inpatient smoking cessation treatment provided | 5 | 1.4 (1.1-1.7) | 23.1 (19.2-27.0)

Evidence

Smoking cessation interventions among hospitalized patients increase rates of smoking cessation. (Strength of Evidence = A)

## Smokers With Psychiatric Comorbidity

Recommendation: Smokers with comorbid psychiatric conditions should be offered smoking cessation treatments identified as effective in this guideline. (Strength of Evidence = C)

Recommendation: Although it is not necessary to assess for psychiatric comorbidity prior to initiating smoking treatment, such assessment may be helpful in that it allows the clinician to prepare for an increased likelihood of smoking relapse or for exacerbation of the comorbid condition in response to nicotine withdrawal. (Strength of Evidence = C)

The term "psychiatric comorbidity" refers to the co-occurrence of smoking with another psychiatric disorder. Psychiatric comorbidity is important to the assessment and treatment of smokers for several reasons:

- Psychiatric disorders are more common among smokers than in the general population. For instance, as many as 30-50 percent of patients seeking smoking cessation services may have a history of depression, and 20 percent or more may have a history of alcohol abuse or dependence (Brandon, 1994; Glassman, Stetnes, Walsh, et al., 1988; Hall, Munoz, Reus, et al., 1993; also cf. Breslau, 1995; Breslau, Kilbey, and Andreski, 1994).
- Smoking cessation or nicotine withdrawal may exacerbate a patient's comorbid condition. For instance, smoking cessation may elicit or exacerbate depression among patients with a prior history of affective disorder (Glassman, 1993; Glassman, Covey, Dalack, et al., 1993).
- As noted in the Specialized Assessment section in Chapter 3, smokers with psychiatric comorbidities have heightened risk for relapse to smoking after a cessation attempt (Brandon, 1994; Glassman, Covey, Dalack, et al., 1993; Hall, Munoz, Reus, et al., 1993).

Although psychiatric comorbidity places smokers at increased risk for relapse, there is also evidence that such smokers can be helped by smoking cessation treatments (Breckenridge, 1990; Burling, Marshall, and Seidner, 1991; Hall, Munoz, and Reus, 1994; Hartman, Jarvik, and Wilkins, 1989; Hartman, Leong, Glynn, et al., 1991). There is currently too little evidence to determine whether smokers with psychiatric comorbidity benefit more from specialized or tailored cessation treatments than from standard treatments (e.g., Hall, Munoz, and Reus, 1994; Zelman, Brandon, Jorenby, et al., 1992). Even though some smokers may experience exacerbation of a comorbid condition upon quitting smoking, most evidence suggests that cessation entails little adverse impact. For instance, patients in inpatient psychiatric units are able to stop smoking with few adverse effects (e.g., little increase in aggression, or nonadherence to treatment; Hurt, Eberman, Slade, et al., 1993; Resnick, 1993). Additionally, there is little evidence that patients with other chemical dependencies relapse to other drug use when they stop smoking (Hurt, Eberman, Slade, et al., 1993). Finally, stopping smoking may affect the pharmacokinetics of certain psychiatric agents (e.g., Hughes, 1993). Therefore, clinicians may wish to monitor closely the actions or side effects of psychiatric medications in smokers making a quit attempt.

## Weight Gain After Smoking Cessation

Recommendation: The clinician should inform smokers that they are likely to gain weight when they stop smoking. The clinician should recommend that smokers not take strong measures (e.g., strict dieting) to counteract weight gain during a quit attempt. Moreover, ex-smokers should wait until they are confident that they will not return to smoking before trying to reduce their weight. (Strength of Evidence = C)

Recommendation: For smokers who are greatly concerned about weight gain, the clinician may prescribe or recommend nicotine gum, which has been shown to delay weight gain after quitting. (Strength of Evidence = A)

Key facts about smoking, smoking cessation, and weight gain follow:

- The majority of smokers who quit smoking gain weight. Most will gain fewer than 10 pounds, but there is a broad range of weight gain, with as many as 10 percent of quitters gaining as much as 30 pounds (Williamson, Madans, Anda, et al., 1991).
- Women tend to gain slightly more weight than men, and for both sexes, African Americans, people under age 55, and heavy smokers (those smoking more than 25 cigarettes/day) are at elevated risk for major weight gain (Emont and Cummings, 1987; Williamson, Madans, Anda, et al., 1991).
- For many smokers, especially women, concerns about weight or fears about weight gain are motivators to start smoking or continue smoking (Gritz, Klesges, and Meyers, 1989; Klesges and Klesges, 1988; Klesges, Meyers, Klesges, et al., 1989).
- Weight gain that follows smoking cessation is a negligible health threat compared with the risks of continued smoking (DHHS, 1990; Williamson, Madans, Anda, et al., 1991).
- No experimentally validated strategies or treatments are effective in preventing postcessation weight gain. In fact, some evidence suggests that attempts to prevent weight gain (e.g., strict dieting) may undermine the attempt to quit smoking (Hall, Tunstall, Vila, et al., 1992; Perkins, 1994; Pirie, McBride, Hellerstedt, et al., 1992).
- Nicotine replacement -- in particular, nicotine gum -- appears to be effective in delaying postcessation weight gain. Moreover, there appears to be a dose-response relation between gum use and weight suppression (i.e., the greater the gum use, the less weight gain occurs). However, once nicotine gum use ceases, the quitting smoker gains an amount of weight that is about the same as if she or he had never used gum (Emont and Cummings, 1987; Gross, Stitzer, and Maldonado, 1989; Nides, Rand, Dolce, et al., 1994).
- Postcessation weight gain appears to be caused both by increased intake (e.g., eating, alcohol consumption) and by metabolic adjustments. The involvement of metabolic mechanisms suggests that even if quitting smokers do not increase their caloric intake, they will still gain some weight (Hatsukami, LaBounty, Hughes, et al., 1993; Hofstetter, Schutz, Jequier, et al., 1986; Klesges and Shumaker, 1992; Moffatt and Owens, 1991; Schwid, Hirvonen, and Keesey, 1992).
- Once a quitting smoker relapses and begins smoking at precessation levels, he or she will usually lose some or all of the weight gained during the quit attempt (Moffatt and Owens, 1991; Noppa and Bengtsson, 1980; Stamford, Matter, Fell, et al., 1986).

The research evidence reviewed above illustrates why weight gain is an important impediment to smoking cessation. Many smokers (especially women) are very concerned about their weight and fear that quitting will produce weight gain. Many also believe that they can do little to prevent postcessation weight except to return to smoking. These beliefs are especially difficult to address clinically because they are congruent with research findings; that is, the beliefs have some basis in fact.

### Recommendations To Address Weight Gain

How should the clinician deal with concerns about weight gain? First, the clinician should neither deny the likelihood of weight gain nor minimize its significance to the patient. Rather, the clinician should inform the patient about the likelihood of weight gain and prepare the patient for its occurrence. However, the clinician should counter exaggerated fears about weight gain given the relatively moderate weight gain that typically occurs. Certain types of information may help prepare the patient for postcessation weight gain (see General Strategy 10).

Second, before and during the quit attempt the clinician should stress that quitting smoking is the patient's primary, immediate priority, and that the patient will be most successful in the long run if he or she does not take strong measures (e.g., strict dieting) to counteract weight gain during a quit attempt (see General Strategy 10).

Third, during the quit attempt, the clinician should offer to help the patient address weight gain (either personally or via referral) once the patient has successfully quit smoking. Specifically, the clinician should recommend that intensive weight control strategies be avoided until the patient is no longer experiencing withdrawal symptoms and is confident that he or she will not return to smoking. Certainly, however, the patient should be encouraged to maintain or adopt a healthy lifestyle, including engaging in moderate exercise, eating plenty of fruits and vegetables, and limiting alcohol consumption.

## Smokeless Tobacco Use

Recommendation: Smokeless tobacco (chewing tobacco and snuff) users should be identified and strongly encouraged to quit. (Strength of Evidence = C)

Recommendation: Smokeless tobacco users should be treated with the same psychosocial cessation interventions recommended for smokers. (Strength of Evidence = B)

Like cigarette smoking, the use of smokeless tobacco, such as chewing tobacco and snuff, produces addiction to nicotine and has serious health consequences. Consumption of smokeless tobacco products has increased in recent years (Glover and Glover, 1992; Marcus, Crane, Shopland, et al., 1989), especially among young males. Clinicians should offer quitting advice and assistance to their patients who use smokeless tobacco.

There is a need for smokeless tobacco information and assistance, but currently little research-based information is available on these topics. A small number of studies have evaluated both multicomponent and brief psychosocial interventions for smokeless tobacco cessation. Results of these evaluations suggest that the same cessation interventions that are effective with smokers are effective with smokeless tobacco users. Currently, there is little evidence on the effectiveness of pharmacologic treatments for smokeless tobacco use. However, nicotine replacement may help smokeless tobacco users just as it does smokers. This is an important area for further research.

Evidence

There is limited evidence that nonpharmacologic treatments used for smoking cessation are also effective in smokeless tobacco cessation. (Strength of Evidence = B)

## Children and Adolescents: Primary Prevention of Tobacco Addiction

Recommendation: Clinicians should provide their pediatric and adolescent patients, and the parents of these patients, with a strong message regarding the importance of totally abstaining from tobacco use. (Strength of Evidence = C)

Recommendation: Cessation interventions shown to be effective with adults should be considered for use with children and adolescents. The content of these interventions should be modified to be developmentally appropriate. Nicotine replacement should be considered only when there is clear evidence of nicotine dependence and a clear desire to quit tobacco use. (Strength of Evidence = C)

The onset of tobacco use is a pediatric concern. Among adult daily smokers, 90 percent tried their first cigarette and 70 percent were daily users at or before age 18. Among high school seniors who had used smokeless tobacco, 79 percent had first done so by the ninth grade (DHHS, 1994). Young people begin to smoke or use tobacco for a variety of reasons related to social norms, advertising, peer pressure, parental smoking, and curiosity, but evidence suggests that nicotine addiction is established rapidly (CDC, 1995).

About three out of every four adolescent smokers have made at least one serious attempt to quit smoking and have failed (Moss, Allen, Giovino, et al., 1992). About 20 percent of high school seniors smoke daily (Green, 1979; Johnston, O'Malley, and Bachman, 1995). Among seniors who smoke daily and expect that they will not be smoking in 5 years, 73 percent are still smoking when surveyed 5-6 years after their senior year (DHHS, 1994).

### Prevention of Tobacco Use

Efforts to prevent tobacco use should be conducted by many types of individuals and groups (e.g., parents, teachers, clergy, government officials, medical societies) and in diverse venues (e.g., home, school, church, youth group). The clinician can target children and adolescents both inside and outside the clinical setting. In the clinical setting, discussion of tobacco-related issues should begin before the onset of adolescence, and preferably before entry into junior high school. These efforts should continue throughout high school. Patient charts should clearly reflect that tobacco has been discussed, and should indicate the smoking status of the patient and parents or caretakers. Clinical prevention activities are listed in General Strategy 11. Prevention strategies useful in more general settings can be found in the recent Institute of Medicine Report, "Growing Up Tobacco Free" (Lynch, Bonnie, and Institute of Medicine Committee on Preventing Nicotine Addiction in Children and Adults, 1994) and Healthy People 2000: National Health Promotion and Disease Prevention Objectives (DHHS, 1991).

### Tobacco Use Cessation in Children and Adolescents

Little research evidence exists regarding either the effectiveness of psychosocial cessation interventions with children and adolescents or the safety and efficacy of pharmacological interventions with this population. Because there is no evidence that nicotine replacement is harmful for children and adolescents, clinicians should consider its use when nicotine dependence is obvious. However, because of the psychosocial and behavioral aspects of smoking in adolescents, clinicians should be confident of the patient's genuine nicotine dependence and desire to quit before instituting pharmacotherapy. Factors such as degree of dependence and body weight should be considered when selecting nicotine replacement therapy dosage.

Children and adolescents may benefit from community- and school-based intervention activities designed especially for these age groups. The messages delivered by these programs should be reinforced by the clinician (DHHS, 1994). Treatment of adolescents and children who smoke is an important research area. Along with clinical trials of interventions, studies of the "experimenters" or occasional tobacco users in this population are needed.

Evidence

Most adolescent tobacco users are addicted to nicotine and report they want to quit but are unable to do so; they experience relapse rates and withdrawal symptoms similar to those reported by adults. Little intervention research involves children and adolescent tobacco users. (Strength of Evidence = C)