# Promoting the Motivation To Quit and Preventing Relapse

## Promoting the Motivation To Quit

Recommendation: For patients not willing to initiate a quit attempt at the time of their health care visit, clinicians should engage in a brief intervention designed to promote motivation to quit. (Strength of Evidence = C)

Enhancing the motivation to quit requires some initial steps described in detail earlier in this guideline. Specifically, patients entering a health care setting should have their smoking status assessed regularly. As a result of a systematic, institutionalized assessment of smoking status, clinicians should advise all smokers to quit and assist those willing to make a quit attempt.

Despite receiving a clinician's advice to quit smoking, many patients are not willing to make a commitment to quit. These patients may be uninformed, concerned about the effects of quitting, or demoralized because of previous relapse. Such patients may respond to a motivational intervention. Motivational interventions are characterized by the "4 Rs": relevance, risks, rewards, and repetition. Clinical components of the 4 Rs are shown in General Strategy 6. Finally, some patients may be discouraged by previous relapses. These patients should be informed that most smokers make repeated cessation attempts before achieving long-term abstinence.

## Relapse Prevention

Recommendation: When clinicians encounter a recent quitter, they should reinforce the patient's decision to quit, review the benefits of quitting, and assist the patient in resolving any residual problems arising from quitting. (Strength of Evidence = C)

Although most relapse occurs early in the quitting process (Kenford, Fiore, Jorenby, et al., 1994), some relapse occurs months or even years after the quit date (Hatziandreu, Pierce, Lefkopoulou, et al., 1990). Therefore, clinicians should engage in relapse prevention interventions designed to reduce the long-term risks of relapse (Brandon, Tiffany, and Baker, 1986). Interventions should be delivered to former smokers who no longer consider themselves actively engaged in the quitting process. (For information on how to reduce relapse risk among those actively engaged in quitting, see General Strategies 1 and 2.)

Relapse prevention interventions can be delivered by means of either prearranged telephone calls or clinic visits, or any time the clinician encounters an ex-smoker. It is vital that a systematic, institutionalized mechanism be in place to identify ex-smokers, because that is a necessary first step in delivering relapse prevention messages.

Relapse prevention interventions can be divided into two categories: minimal practice and prescriptive interventions.

### Minimal Practice

Minimal relapse prevention interventions should be part of every primary care encounter with a patient who has recently quit (General Strategy 7). Because most relapse occurs within the first 3 months after quitting, relapse prevention is especially appropriate during this period (DHHS, 1994). Relapse prevention activities can easily be incorporated into cessation treatments such as problem-solving counseling (see General Strategy 1).

### Prescriptive Interventions

These relapse prevention components are individualized based on information obtained about problems the patient has encountered in maintaining abstinence (General Strategy 8). These more intensive relapse prevention interventions may be delivered through primary care or through a specialized clinic or program.