# Recommendations for Three Target Audiences

## Primary Care Clinicians

### Background

Primary care and other clinicians are uniquely poised to assist patients who smoke, in that they have extraordinary access to this population. At least 70 percent of smokers see a physician each year and more than 50 percent see a dentist (Hayward, Meetz, Shapiro, et al., 1989; Tomar, Husten, and Manley, 1996). Moreover, 70 percent of smokers report that they want to quit and have made at least one self-described serious attempt to quit (CDC, 1994). Finally, smokers cite a physician's advice to quit as an important motivator for attempting to stop (NCI, 1994; Ockene, 1987; Pederson, 1982). The importance of clinical intervention with patients who use tobacco is highlighted by its inclusion as a national health goal in Healthy People 2000: National Health Promotion and Disease Prevention Objectives(DHHS, 1991).

Unfortunately, clinicians are not capitalizing fully on this unique opportunity. Only about half of current smokers report having ever been asked about their smoking status or urged to quit (Anda, Remington, Sienko, et al., 1987; CDC, 1993b; Frank, Winkleby, Altman, et al., 1991). Fewer still have received specific advice on how to quit smoking successfully.

Why don't clinicians consistently confront tobacco use among their patients? Some clinicians' reluctance to intervene may be attributed, in part, to time constraints, a perceived lack of skills to be effective in this role, frustration owing to low success rates, or even a belief that smoking cessation is not an important professional responsibility (Jaen, Stange, and Nutting, 1994). Several changes have been proposed to increase clinicians' intervention with smokers: (a) health care delivery practices must change so that smoking cessation interventions are institutionalized, (b) clinicians and their patients must be reimbursed by insurers for smoking cessation counseling and pharmacotherapy, (c) clinicians must adjust their goals so that motivational interventions are offered to smokers who are not yet committed to quitting (Biener and Abrams, 1991; Curry, Wagner, and Grothaus, 1990; Prochaska and Goldstein, 1991), and (d) standards of health care delivery must reflect the health care system's obligation to intervene in a timely and appropriate manner with patients who smoke (Fiore and Baker, 1995; Kottke and Solberg, 1995).

In this section of the guideline, specific recommendations relevant to primary care clinicians (physicians, nurses, dentists, respiratory therapists, etc.) are presented. The goals of these recommendations are clear: to change clinical culture and practice patterns to ensure that every patient who smokes is offered treatment. The recommendations in this section are selected from among the findings presented in Chapter 3. The recommendations underscore a central theme: It is essential to provide a brief but effective cessation intervention for all tobacco users at each clinical visit. Several observations are relevant to this theme. First, institutional changes in clinical practice are necessary to ensure that all patients who smoke are identified for intervention (see section below on Health Care Administrators, Insurers, and Purchasers). Second, the compelling time limitations on practicing primary care physicians in the United States today (median visit = approximately 12 minutes; Gilchrist, Miller, Gillanders, et al., 1993) often require brief interventions, although more intensive interventions produce greater success. Third, although many smokers are reluctant to seek out intensive cessation programs (Lichtenstein and Hollis, 1992), they nevertheless can receive treatment every time they visit any type of clinician.

### Training Clinicians To Intervene With Their Patients Who Smoke

Clinicians must be trained in effective smoking cessation interventions if these guideline recommendations are to be implemented. The importance of training is clear in that clinicians report lack of relevant knowledge as a significant barrier to intervening with their patients who smoke (Cummings, Giovino, Sciandra, et al., 1987; Scott and Neighbor, 1985; Wechsler, Levine, Idelson, et al., 1983).

Training should be directed at clinicians-in-training as well as practicing clinicians. For clinicians-in-training, most disciplines do not currently provide training, or require competency, in smoking cessation interventions. For example, a recent NCI expert panel found that medical schools do not consistently train students in effective smoking cessation interventions (Fiore, Epps, and Manley, 1994). The panel recommended that a specific curriculum devoted to smoking cessation be included as part of each medical student's education. Similar recommendations would be relevant to virtually all other clinical disciplines. Training in smoking intervention should not only transmit essential treatment skills but also inculcate the belief that smoking cessation treatment is a standard of good practice (Kottke, Solberg, Brekke, et al., 1992).

Practicing clinicians would also benefit from continuing education that addresses smoking cessation. This guideline recommends that clinicians be reimbursed for smoking cessation treatment and that their intervention activities be tracked. Either of these policies should foster increased interest in smoking cessation training among practicing clinicians.

Several factors would promote the training of clinicians to intervene in smoking cessation activities:

- Inclusion of smoking cessation interventions in the required curricula of all clinical disciplines.
- Inclusion of questions on effective smoking cessation interventions in licensing and certification exams for all clinical disciplines.
- Adoption by specialty societies of a uniform standard of competence in smoking cessation intervention for all members.

Finally, clinicians who smoke should participate in an additional type of education or training -- they should enter smoking cessation treatment programs in order to stop smoking permanently. Clinicians have an important role as nonsmoking models for their patients. An encouraging finding has been the dramatic decrease in smoking rates reported among many types of clinicians. In a recent report on tobacco-use prevalence by occupation, the rate of smoking was noted to be 5.5 percent among physicians, 7.4 percent among dentists, 8.7 percent among physical therapists, and 22.0 percent among registered nurses (Nelson, Emont, Brackbill, et al., 1994). All of these prevalence rates are lower than tobacco-use rates in the general population. All clinicians who currently smoke should seek out effective smoking cessation treatments recommended in this guideline.

### Recommendations for Primary Care Clinicians

Recommendations for primary care clinicians are based on the evidence described in the first four sections of Chapter 3, as well as on panel opinion. These recommendations assume that office systems will be implemented to institutionalize smoking cessation assessment and intervention (see section on Health Care Administrators, Insurers, and Purchasers). They also are designed to be brief, requiring 3 minutes or less of direct clinician time. Finally, these recommendations are consistent with those produced by NCI (Glynn and Manley, 1990) and the American Medical Association (AMA) (American Medical Association, 1994), as well as others (e.g., Kottke, Solberg, and Brekke, 1990; Mecklenburg, Christen, Gerbert, et al., 1991).

The AHCPR guideline recommendations emphasize the importance of systematically identifying all smokers (see For the Primary Care Clinician: Strategy 1), strongly advising all smokers to quit (see For the Primary Care Clinician: Strategy 2), and determining patients' willingness to make a quit attempt (see For the Primary Care Clinician: Strategy 3). The patient not willing to commit to quitting should receive a motivational intervention to promote subsequent quit attempts (see Chapter 4, Promoting the Motivation to Quit). When the patient is willing to make a quit attempt, primary care clinicians may assist by asking the patient to set a quit date, preparing the patient for the quit date, encouraging nicotine replacement therapy, providing self-help materials, and providing key advice (see For the Primary Care Clinician: Strategy 4). The clinician should refer the patient to intensive treatments when the clinician views such treatments as appropriate (e.g., if the patient has relapsed repeatedly following minimal interventions) or if the patient prefers such treatments (see next section). All patients attempting quitting should have followup contact scheduled (see For the Primary Care Clinician: Strategy 5).

## Tobacco Cessation Specialists and Programs

### Background

Smoking cessation specialists are not defined by their professional affiliation or by the field in which they trained. Rather, the specialist views smoking cessation as a critical professional role, possesses skills relevant to cessation activities, and is often affiliated with programs offering intensive cessation interventions or services (programs with staff dedicated to smoking interventions, where treatment involves multiple counseling sessions, and so on).

Specialists are a vital resource in smoking cessation efforts. For example, many effective smoking cessation strategies now widely disseminated (e.g., skills for coping with urges to smoke) were developed by specialists conducting intensive intervention programs. As major contributors to cessation research, specialists exert a cumulative effect greater than their number.

Also, specialists play an important role in service delivery -- especially through the provision of intensive cessation interventions. Some smokers seek out and prefer the intensive interventions offered by specialists. There is substantial evidence that such programs produce higher success rates than do less intensive interventions (as indicated by several findings of the present guideline). In addition, the cessation interventions offered by specialists are important because many nonspecialists do not consistently and reliably intervene with smokers.

Although the specialist definitely contributes greatly to smoking cessation efforts, constraints limit the impact of the specialist's service delivery activities. Only a minority of smokers participate in the intensive programs typically offered by specialists (Fiore, Novotny, Pierce, et al., 1990). Moreover, not enough resources are available to offer intensive programs to all smokers wanting to quit. Such considerations suggest that, in the future, the specialist may contribute to smoking cessation efforts through activities in addition to service delivery per se, such as the following:

- Serving as a resource to nonspecialists who offer smoking cessation services as part of general health care delivery. This might include training nonspecialists in counseling strategies, providing consultation on difficult cases, and providing specialized assessment services.
- Developing and evaluating changes in office/clinic procedures that increase the rates at which smokers are identified and treated.
- Conducting evaluation research to determine the effectiveness of ongoing smoking cessation activities in relevant institutional settings.
- Developing and evaluating innovative treatment strategies that increase the effectiveness of smoking cessation interventions. For example, "treatment matching" (e.g., Hall, Munoz, and Reus, 1994; Zelman, Brandon, Jorenby, et al., 1992), "stepped-care" approaches (Abrams, Orleans, Niaura, et al., 1993, in press; Orleans, 1993), smoking cessation interventions for patients with psychiatric comorbidity (Hughes and Frances, 1995; Hurt, Eberman, Croghan, et al., 1994), the treatment of severely dependent smokers (Hurt, Dale, Offord, et al., 1992), and proactive telephone counseling during followup (Zhu, Stretch, Balabanis, et al., 1996) represent five such innovative approaches.

### Recommendations for Tobacco Cessation Specialists and Programs

Given that the specialist may assume diverse roles regarding smoking cessation -- treatment, assessment, training of nonspecialists, and program development and evaluation -- it is apparent that virtually all of the information in the guideline might be important to the specialist. However, highlighted in For the Specialist: Strategy 1 are guideline findings that seem particularly relevant to the specialist's implementation of intensive cessation programs. The above findings lead to the following recommendations regarding intensive smoking cessation programs (see For the Specialist: Strategy 2). Of course, implementation of these recommendations depends on factors such as resource availability, time constraints, and so on.

## Health Care Administrators, Insurers, and Purchasers

### Background

Although clinical practice guidelines have traditionally focused on the role of the individual clinician, promoting smoking cessation in the United States requires a broader approach involving health care delivery administrators, insurers, and purchasers. Why broaden the scope of this document beyond the individual clinician? Smoking cessation efforts directed solely at the individual clinician have yielded disappointing results. National data suggest that, in a given visit with a clinician, most smokers are not advised and assisted with cessation (CDC, 1993b). Factors that contribute to this problem include failure to (a) include smoking assessment and cessation in the performance expectations of clinicians and (b) provide clinicians with an environment that supports systematic intervention with smokers. Without supportive systems, policies, and environmental prompts, the individual clinician cannot be counted on to assess and treat tobacco use reliably. In addition, an increasing number of Americans are receiving their health care in managed care settings. The structure of managed care environments provides new opportunities to identify and treat patients who smoke. These factors indicate that responsibility for smoking cessation treatment must be redistributed; just as every clinician has a professional responsibility to assess and treat tobacco users, health care administrators, insurers, and purchasers have a responsibility to craft policies, provide resources, and display leadership in fostering smoking cessation efforts.

It is important to emphasize that smoking cessation treatments (both pharmacotherapy and counseling) are not consistently provided as paid services for subscribers of health insurance packages (Group Health Association of America, 1993), with one survey demonstrating that as few as 11 percent of health insurance carriers provided coverage for treatment of nicotine addiction (Gelb, 1985). This lack of coverage is particularly surprising given that studies have shown that physician counseling against smoking is at least as cost-effective as several other preventive medical practices, including the treatment of mild or moderate hypertension or high cholesterol (Cummings, Rubin, and Oster, 1989). These and other findings resulted in the recent addition of a new objective to the national health promotion and disease prevention objectives for the year 2000:

Increase to 100 percent the proportion of health plans that offer treatment of nicotine addiction (e.g., tobacco use cessation counseling by health care providers, tobacco use cessation classes, prescriptions for nicotine replacement therapies, and/or other cessation services) (DHHS, 1995).

### Cost-Effectiveness of Smoking Cessation Interventions

Smoking cessation treatments are not only clinically effective, they have economic benefits as well. It is vital that all three audiences targeted in this guideline recognize that smoking cessation treatments ranging from brief clinician advice to specialist-delivered intensive programs are cost-effective in relation to other sorts of medical interventions. Cost-effectiveness analyses (Cummings, Rubin, and Oster, 1989; Eddy, 1981, 1986; Oster, Huse, Delea, et al., 1986) have shown that smoking cessation treatment compares quite favorably with routine medical interventions such as the treatment of hypertension and hypercholesterolemia and preventive interventions such as periodic mammography. In fact, Eddy referred to smoking cessation treatment as the "gold standard" of preventive interventions (Eddy, 1992).

Although only a minority of smokers will achieve success in response to a single application of treatment, clinicians, specialists, and administrators should not forget or ignore the significant health and economic benefits of cessation treatments relative to their costs. The cost-effectiveness of guideline recommendations for smoking cessation will be addressed in detail in an ancillary document sponsored by AHCPR.

### Recommendations for Health Care Administrators, Insurers, and Purchasers

Health care delivery administrators, insurers, and purchasers can promote tobacco cessation through a systems approach. Purchasers (usually corporations, companies, or other consortia that purchase health care benefits for a group of individuals) should consider making tobacco assessment, counseling, and treatment a contractual obligation of the health care insurers and/or providers that sell them services. In addition, health care administrators and insurers must provide clinicians with assistance to ensure that institutional changes promoting smoking cessation interventions are universally and systematically implemented. A number of institutional policies would facilitate these interventions:

- Implement a tobacco-user identification system in every clinic (see For Health Care Administrators, Insurers, and Purchasers: Strategy 1).
- Provide education, resources, and feedback to promote provider intervention (see For Health Care Administrators, Insurers, and Purchasers: Strategy 2).
- Dedicate staff to provide smoking cessation treatment identified as effective in this document and assess the delivery of this treatment in staff performance evaluations (see For Health Care Administrators, Insurers, and Purchasers: Strategy 3).
- Promote hospital policies that support and provide smoking cessation services (see For Health Care Administrators, Insurers, and Purchasers: Strategy 4).
- Include smoking cessation treatment (both pharmacotherapy and counseling), identified as effective in this guideline, as paid services for all subscribers of health insurance packages (see For Health Care Administrators, Insurers, and Purchasers: Strategy 5).
- Reimburse fee-for-service clinicians for delivery of effective smoking cessation treatments and include these interventions among the defined duties of salaried clinicians (see For Health Care Administrators, Insurers, and Purchasers: Strategy 6).