# Overview

## Rationale for Guideline Development

The Agency for Health Care Policy and Research (AHCPR) convenes expert panels to develop clinical guidelines for health care practitioners. AHCPR determines the need for guidelines for a given condition based on several factors, including prevalence, related morbidity and mortality, economic burden imposed by the condition, variation in clinical practice related to the condition, availability of methods for improvement of care, and availability of data on which to base recommendations for care.

Tobacco use has been cited as the chief avoidable cause of illness and death in our society, responsible for more than 400,000 deaths in the United States each year. Smoking is a known cause of cancer, heart disease, stroke, and chronic obstructive pulmonary disease (Centers for Disease Control [CDC], 1993a). Tobacco use is surprisingly prevalent, given the health dangers it presents and the public's awareness of those dangers (DHHS, 1989). Recent estimates are that 25 percent of Americans smoke (CDC, 1994). Moreover, smoking prevalence among adolescents appears to be rising, with more than 3,000 children and adolescents becoming regular users of tobacco each day. This ensures that a new generation of Americans will be addicted to nicotine and at risk for the host of harmful consequences of tobacco use. Tobacco use is not only dangerous to individuals, it yields staggering societal costs as well. The estimated smoking-attributable cost for medical care in 1993 is $50 billion, and the cost of lost productivity and forfeited earnings due to smoking-related disability is estimated at $47 billion per year (Herdman, Hewitt, and Laschober, 1993).

Despite the tragic health consequences of smoking, physicians and other health care clinicians often fail to assess and treat tobacco use consistently and effectively. For instance, only half of smokers seeing a primary care physician in the past year report being asked about their smoking (Robinson, Laurent, and Little, 1995), and only a minority of smokers report being advised to quit (CDC, 1993b). This failure to assess and intervene exists in the face of substantial evidence that even brief smoking cessation treatments can be effective (e.g., Fiore, Smith, Jorenby, et al., 1994; Glynn and Manley, 1990; Russell, Wilson, Taylor, et al., 1979).

The evidence reviewed above suggests that tobacco use presents a rare confluence of circumstances: (1) a highly significant health threat, (2) a disinclination among clinicians to intervene consistently, and (3) the presence of effective, preventive interventions. The last point is buttressed by overwhelming evidence that smoking cessation interventions, if delivered in a timely and effective manner, greatly reduce the smoker's risk of suffering from smoking-related disease (DHHS, 1990). Indeed, it is difficult to identify a condition in developed countries that presents such a mix of lethality, prevalence, and neglect, despite effective and readily available interventions.

Clinicians know that tobacco use is a serious health problem. But significant barriers exist that interfere with clinicians' assessment and treatment of smokers. Many clinicians lack knowledge about how to identify smokers quickly and easily, which treatments are efficacious, how such treatments can be delivered, and the relative efficacies of different treatments. Clinicians may fail to intervene because they are unaware of the availability of efficacious, brief treatments that are ideal for clinical settings. Or, clinicians may fail to intervene because of inadequate clinic or institutional support for routine assessment and treatment of tobacco use.

This guideline addresses these barriers on the basis of a careful evaluation and synthesis of relevant existing scientific literatures. The guideline comprises specific evidence-based recommendations to guide clinicians and smoking cessation specialists in their tobacco intervention efforts. Additional specific recommendations guide insurers, managed care providers, and other health care administrators in their efforts to develop and implement institutional supports for reliable assessment and treatment of tobacco use. The National Cancer Institute (NCI) projects that if 100,000 physicians were to help 10 percent of their patients who smoke to stop each year, the number of smokers in the United States would drop by an additional 2 million people annually (Fiore, Pierce, Remington, et al., 1990). Even greater cessation would occur if other types of health care clinicians (e.g., nurses) would also intervene with their patients who smoke. This guideline, therefore, is a potentially powerful tool in the mission to curtail the greatest preventable cause of death and disability in the United States today.

## Organization of the Guideline and Other Products

This guideline is divided into five chapters. Chapter 1, Overview, provides an overview and rationale for the guideline, as well as a detailed description of the methodology used to review the scientific literature and develop the guideline.

Chapter 2, Recommendations for Three Target Audiences, is directed at the three key audiences for this guideline -- primary care clinicians, smoking cessation specialists, and health care delivery administrators, insurers, and purchasers. These sections are designed as stand-alone guides for implementing the relevant components of the guideline.

Chapter 3, Evidence,presents the evidentiary basis for the guideline recommendations. The sections within this chapter are organized around the Model for Tobacco Cessation Evidence (Figure 1); each section describes the scientific data that support the components of the evidence model. The section on Screen for Tobacco Use provides the scientific evidence that forms the basis for recommendations regarding the identification of tobacco users. This section corresponds to the "Screen for Tobacco Use" box in Figure 1. The section on Advice to Quit Smoking characterizes the evidence that supports the importance of clinicians advising every tobacco user to quit. This section corresponds to the "Advise" box in Figure 1. For those smokers who are willing to make a quit attempt, the section on Specialized Assessment addresses the formal assessment of smokers prior to a cessation attempt. This section corresponds to the "Assess" box of Figure 1. The section on Interventions, the longest section of the chapter, provides the scientific evidence evaluating various characteristics and types of tobacco cessation interventions. This corresponds to the "Intervene" box of Figure 1. Finally, the evidence supporting the importance of followup interventions after a smoker has quit is described in the section on Followup Assessment and Procedures. This corresponds to the "Followup Procedures" box in Figure 1.

Figure 1. Model for tobacco cessation evidence

Chapter 4 of the guideline, Promoting the Motivation to Quit and Preventing Relapse, addresses two issues not covered in the previous chapters. The first section addresses strategies to motivate smokers not willing to make a quit attempt at this time. The second section provides recommendations to prevent relapse among individuals trying to quit.

Chapter 5, Special Populations and Topics, provides specific information on specific populations (women, racial and ethnic minorities, hospitalized patients, children and adolescents) and special topics (weight gain upon quitting, smokeless tobacco use) not otherwise addressed in the guideline. These special populations and topics are not identified in Figure 1.

In addition to this Clinical Practice Guideline, a larger document, the Smoking Cessation Guideline Technical Report (the "technical report"), contains more detailed information on the methodology employed in developing this guideline. This technical report may be obtained by contacting the National Technical Information Service. Additionally, two quick reference guides are available, as well as a consumer guide.

## Guideline Development Methodology

### Introduction

The panel attempted, through the recommendations in the guideline, to provide clinicians with effective strategies to assist patients who use tobacco. Recommendations were influenced by two goals. The first was to be as clear as possible in identifying those treatment strategies found to be efficacious. The second was that recommendations be made in such a way that they could be implemented across diverse clinical settings and patient populations.

The guideline is based on systematic reviews of the available scientific literature. The reviews involved a comprehensive examination of literature published from 1976 through 1994. The panel identified randomized controlled trials as the strongest level of evidence for evaluation of treatment efficacy. Thus, evidence derived from randomized controlled trials serves as the basis for almost all recommendations contained in this guideline. However, the panel occasionally made recommendations in the absence of randomized controlled trials. It did so when faced with an important clinical practice issue for which considerable suggestive evidence existed. The panel clearly identified the level or strength of evidence that served as the basis for each of its recommendations.

### Topics Included in the Guideline

The panel identified tobacco use as the targeted condition and all tobacco users as the clinical population of interest. All tobacco cessation interventions were examined, as well as interventions aimed at modifying both clinician and health care delivery system behavior.

Interventions for the primary prevention of tobacco use were not examined in detail (see the Section in Chapter 5, Children and Adolescents: Primary Prevention of Tobacco Addiction) with the exception of interventions directly relevant to clinical practice. Because of the importance and complexity of the primary prevention of tobacco initiation, the panel recommended that primary prevention be addressed in a separate clinical practice guideline. In addition, community-level interventions (e.g., mass media campaigns) that were not directly relevant to primary care practice settings were not addressed.

This guideline was designed for three primary audiences: primary care clinicians, smoking cessation specialists, and health care administrators/insurers/purchasers. The guideline was also designed to be appropriate for use in a wide variety of practice settings including private practice, health maintenance organizations, public health department clinics, hospitals, school or work site clinics, and so on.

### Guideline Development Process

This guideline was developed over 2 years beginning in late 1993. A distillation of the guideline development process is illustrated in Figure 2.

Figure 2. Guideline development process

### Search and Review of the Literature

The literature was reviewed systematically by (a) establishing a priori criteria for relevant studies, (b) reviewing abstracts and articles selected by computer searches and by scanning bibliographies, (c) compiling and reviewing the full articles, (d) compiling evidence tables summarizing these articles, and (e) conducting meta-analyses where possible.

#### Inclusion Criteria

Approximately 3,000 articles were reviewed to identify the literature appropriate for evaluation. The appropriateness of an article was determined by applying the criteria for inclusion established a priori by the panel. The criteria were that the article (a) reported the results of a randomized, controlled trial of a tobacco-use cessation intervention, (b) provided followup results at a timepoint at least 5 months after the quit date, (c) was published in a peer-reviewed journal, (d) was published between 1975 and 1994, and (e) was published in English. As a result of this review, more than 300 articles were included in our final database. A list of these references may be obtained by contacting AHCPR and is available for online retrieval (see Availability of Guidelines on inside back cover for more information).

When individual authors produced multiple articles meeting inclusion criteria, each article was carefully screened to ensure that it, in fact, represented an independent trial. Where two articles appeared to report data from the same group of subjects, only the most complete article was used to generate data for the analyses.

In some cases, panel conclusions were based partly on the results of previously published meta-analyses. Published meta-analyses were used when they (a) synthesized data from related sets of randomized clinical trials of smoking cessation methods, (b) were published in peer-reviewed journals, (c) were published between 1975 and 1994, and (d) were published in English.

#### Selection of Evidence

Only published, peer-reviewed randomized controlled trials were considered to provide strong evidence in support of guideline recommendations. This decision was based on the judgment that randomized controlled trials are the clearest scientific method for judging comparative efficacy. The panel made this decision recognizing the limitations of randomized controlled trials, particularly considerations of generalizability with respect to patient selection and treatment quality.

#### Preparation of Evidence Tables

To evaluate the literature systematically, three literature reviewers independently read and scored each article that met inclusion criteria. The reviewers then met and compared coding. Any discrepancies that could not be resolved were adjudicated by the project director, panel chair, and/or senior scientific consultant. The data were then compiled and used in relevant analyses.

#### Analysis of Treatment Effect

The success of a treatment studied in a randomized controlled trial can be reported in a number of ways. For instance, what percentage of patients randomized to a treatment successfully quit? This question can be answered by an intent-to-treat analysis that uses the number of patients who quit smoking (regardless of whether they remained in the study) as the numerator and the number randomized to the treatment as the denominator.

A modified intent-to-treat analysis was generally used in this guideline. The denominator for this analysis was the number of patients randomized to the treatment, but in most studies, the numerator was the number of abstinent patients who were contacted at followup. In other words, smokers who could not be contacted at followup were not considered abstinent and were not included in the numerator. This modification was made because few studies presented sufficient data to permit calculation of true intent-to-treat numbers, whereas many provided enough information to permit calculation of the modified percentage.

#### Outcome Data

A study was required to provide outcome data with followup at least 5 months after the designated quit day. Five months was chosen to balance the needs for (a) a large pool of studies for meta-analyses and (b) the desire to examine only clinically important outcomes (i.e., long-term cessation). These long-term outcome data provided the basis of virtually all cessation analyses contained in this guideline. (The one exception is that the meta-analysis of cessation treatments in pregnant women contained somewhat shorter followup periods.) Panel staff also coded the presence of biochemical confirmation of self-reported abstinence. In most major meta-analyses, panel staff investigated whether studies using biochemical confirmation yielded different results than did studies without this design feature. Including or excluding studies that lacked biochemical verification had little impact on meta-analysis results. Therefore, meta-analyses presented in the guideline reflect a pooling of studies with and without biochemical confirmation.

### Meta-Analytic Techniques

#### Methodology and Limitations

The principal analytic technique used in this guideline was meta-analysis. This statistical technique estimates the impact of a treatment or variable across a set of related investigations. A complete and detailed review of the meta-analytic methods used in the guideline can be found in the technical report. The primary meta-analytic model used in the guideline was logistic regression using random effects modeling. The panel methodologists chose to employ random effects modeling, assuming that both the subject populations and the treatment elements analyzed would vary from study to study (e.g., "general problem-solving" counseling might be done somewhat differently at two different sites). Random effects modeling is well suited to accommodate such variation among studies (DerSimonian and Laird, 1986).

The initial step in meta-analysis was the selection of studies that were relevant to the treatment characteristic being evaluated. After relevant studies were identified (e.g., those that contained a self-help intervention if self-help treatments were being evaluated), panel staff reviewed the studies to ensure that they passed screening criteria. Some screening criteria were general (e.g., appropriate randomization), whereas other criteria were specific to the type of treatment characteristic evaluated (e.g., in the analysis of clinicians, screening ensured that differences in clinicians were not confounded by differences in pharmacotherapy status). The technical report contains lists and descriptions of all screening criteria.

Several factors can compromise the internal validity of the meta-analyses. For example, publication biases (particularly the tendency to publish only those studies with positive findings) may result in biased summary statistics. In addition, either the magnitude or the significance of the findings of the meta-analyses may be influenced by factors such as the frequency with which treatments occurred in the data set, and by the extent to which treatments co-occurred with other treatments. All else being equal, a treatment that occurs infrequently in the data set is less likely to be found significant than a more frequently occurring treatment. And, when two treatments co-occur frequently in the same groups of subjects, it is difficult to apportion statistically the impact of each.

Threats to the external validity of the meta-analysis relate primarily to the generalizability of the study populations. However, conducting separate meta-analyses based on the populations under study yielded generally similar results across a variety of treatment dimensions. For instance, meta-analyses that involved subjects seeking out smoking cessation treatment ("self-selected") yielded results similar to meta-analyses in which subjects received treatment without taking steps to seek it, such as when it is an integral part of a health care visit ("all-comers"). No other population characteristics (e.g., years smoked, packs per day) were explored in meta-analyses.

In summary, with the exception of the caveats discussed above, the meta-analytic techniques provide a valid synthesis of smoking cessation treatment outcome data and identify treatment features or elements that are effective across a group of related investigations.

### Strength of Evidence

Every recommendation made by the panel bears a strength-of-evidence rating that indicates the quality and quantity of empirical support for the recommendation. The three ratings are described below:

- A. Multiple well-designed randomized clinical trials, directly relevant to the recommendation, yielded a consistent pattern of findings.
- B. Some evidence from randomized clinical trials supported the recommendation, but the scientific support was not optimal. For instance, either few randomized trials existed, the trials that did exist were somewhat inconsistent, or the trials were not directly relevant to the recommendation. An example of the last point would be the case where trials were conducted using a study population that differed from the target population of the recommendation.
- C. Reserved for important clinical situations where the panel achieved consensus on the recommendation in the absence of relevant randomized controlled trials. The panel declined to make recommendations when there was no relevant evidence or the evidence considered was too weak or inconsistent.

Not every evidence statement is used to support a recommendation. Therefore, a recommendation may be directly relevant to only a subset of the evidence statements in the same guideline section. Thus, within a section, some evidence statements may carry different strength ratings than does a particular recommendation.

### Interpretation of Meta-Analysis Results

The meta-analyses yielded logistic regression coefficients that were converted to odds ratios. The meaning or interpretation of an odds ratio can be seen most easily by means of an example depicted in a 2 x 2 table. Table 1contains data showing the relation between maternal smoking and low birth weight in infants. Data are extracted from Hosmer and Lemeshow (1989). The odds of a low birth weight infant if the mother smokes are 30:44, or 0.68 to 1. The odds of a low birth weight infant if the mother does not smoke are 29:86, or 0.34 to 1. The odds ratio is thus (30/44)/(29/86) = 2.02 to 1.

Table 1. Relation between maternal smoking and low birth weight in infants

| | Maternal smoking
| | Yes | No
Low birth weight | Yes | 30 | 29 | 59
| No | 44 | 86 | 130
| | 74 | 115 | 189

Therefore, the odds ratio can be seen roughly as the odds of an outcome on one variable, given a certain status on another variable(s). In the case above, the risk of a low birth weight infant is about double for women who smoke compared with those who do not.

Once odds ratios were obtained from meta-analyses, the statistical methodologist estimated 95 percent confidence intervals around the odds ratios. An odds ratio is only an estimate of a relation between variables. The 95 percent confidence interval presents an estimate of the accuracy of the particular odds ratio obtained. If the confidence interval for a given odds ratio does not include "1," then the odds ratio represents a statistically significant effect at the .05 level. The confidence intervals will generally not be perfectly symmetrical around an odds ratio because of the distributional properties of the odds ratio.

After computing the odds ratios and their confidence intervals, the statistical methodologist then converted the odds ratios to cessation percentages and their 95 percent confidence intervals. Cessation percentages indicate the estimated long-term smoking cessation rate achieved under the tested treatment or treatment characteristic. The cessation percentage results are approximate estimates derived from the odds ratio data (Eddy and Hasselblad, 1992). Therefore, they essentially duplicate the odds ratio results but are presented because their meaning may be clearer for some readers.

### How To Read the Data Tables

Table 2 depicts a table of results from one of the meta-analyses reported in this guideline. This table presents results from the analysis of the effects of different durations of treatment (in weeks) on outcome (see the section in Chapter 3, Interventions). In this table, the comparison condition, or "reference group," for determining the impact of different treatment durations, was smokers given brief cessation interventions -- ones lasting less than 2 weeks (all sessions were delivered within a 2-week period). The "Estimated odds ratio" column reveals that treatment groups receiving treatments lasting either 2-4 weeks or 4-8 weeks both had odds ratios of 1.6. In both cases, the odds ratio indicates a significant effect, because the lower boundary of the confidence interval did not include "1." Treatments lasting more than 8 weeks had the largest odds ratio (2.7). This odds ratio means that when a smoker receives long-duration treatments (greater than 8 weeks), in contrast to treatments lasting fewer than 2 weeks, the likelihood is more than doubled that he or she will quit smoking. This effect is significant, because the lower confidence interval boundary (2.2) does not include "1.

Table 2. Efficacy of and cessation rates for various durations of treatment (n = 55 studies)

Duration | Number of arms | Estimated odds ratio (95 C.I.) | Estimated cessation rate (95 C.I.)
< 2 weeks (reference group) | 101 | 1.0 | 10.4
2 to < 4 weeks | 14 | 1.6 (1.3-2.0) | 15.6 (12.9-18.3)
4-8 weeks | 12 | 1.6 (1.2-2.1) | 16.1 (12.4-19.7)
> 8 weeks | 15 | 2.7 (2.2-3.2) | 23.8 (20.6-27.1)

The column labeled "Estimated cessation rate" shows the cessation percentages for the various treatment durations. For instance, the reference group conditions (duration less than 2 weeks) in the analyzed data set were associated with a smoking cessation abstinence rate of 10.4 percent. As suggested by the odds ratio data reviewed above, treatment durations lasting 2-8 weeks produced moderate increases in cessation rates (to about 16 percent), whereas the longest treatments (greater than 8 weeks) produced substantial increases (to over 23 percent). The statistical significance of the three longer treatment durations is indicated by the fact that their confidence intervals do not overlap the cessation rate produced by the less-than-2-week (reference group) condition.

The column labeled "Number of arms" lists the number of treatment conditions or groups across all analyzed studies that fell within the various treatment duration categories (e.g., in 15 treatment arms, treatment exceeded 8 weeks). Therefore, this column depicts the number of treatment conditions or groups relevant to each analyzed category.

Two additional factors deserve to be highlighted regarding the data tables in this guideline. First, all outcome data (both odds ratios and cessation rates) are based exclusively on studies that provided long-term followup, defined as quit rates at 5 months or greater followup points. When quit rates were provided for multiple long-term endpoints, efficacy data from the endpoint closest to 6 months were used. Second, all outcome data are based on all studies that met inclusion criteria (see Methodology and Limitations subsection above). Therefore, the outcome data in the tables include studies with "all-comers" (individuals who did not choose to be part of a smoking cessation intervention) and "self-selected" populations, as well as studies with and without biochemical confirmation. As previously mentioned, there were essentially no differences identified when these comparison populations, or studies with different biochemical confirmation statuses, were analyzed separately. Despite the present results, biochemical confirmation may contribute to the internal validity of controlled clinical trials.

### Caveats to Recommendation Use

In applying these guideline recommendations, the reader should note some caveats. First, an absence of studies should not be confused with a proof of lack of efficacy. In certain situations, there was little direct evidence regarding the efficacy of various treatments, and in these cases the panel usually rendered no opinion.

Moreover, the emphasis of this guideline was to identify efficacious interventions, not to rank-order interventions in terms of efficacy. The panel chose not to emphasize comparisons among efficacious interventions for several reasons. First, the most important goal of the analytic process was to identify all of those interventions that are efficacious. Second, selection or use of particular intervention techniques or strategies is usually a function of practical influences: time available, training of the clinician, patient preference, cost, and so on. The panel believed that clinicians should choose from among the efficacious interventions those that are feasible given existing circumstances. An excessive emphasis on relative efficacy might discourage clinicians from using interventions that have a small, but reliable, impact on smoking cessation. Finally, data were often inadequate or unavailable to make adequate statistical comparisons of different types of interventions. For example, although numerous studies have investigated the efficacy of both the nicotine patch and nicotine gum relative to placebo treatments, no published randomized trials directly compared the efficacy of these two pharmacotherapies.

Despite a lack of emphasis on the rank-ordering of interventions, some interventions were so superior to control or no-treatment conditions that the panel clearly identified them as superior to other intervention. For instance, although even minimal person-to-person contact can increase smoking cessation rates over no-treatment conditions, there is little doubt that longer person-to-person interactions have an even greater impact.

### Eliciting and Addressing Public Opinion

At the start of the second panel meeting, an open forum was held in Washington, DC, on November 9, 1994, to receive input from the general public. This open forum meeting was publicized in the Federal Register. A variety of issues were raised by individuals from many disciplines, including physicians, nurses, and psychologists; professional groups; individual medical consumers; and other concerned parties. Suggestions from the public forum were reviewed and incorporated into the guideline when appropriate.

### External Review of the Guideline

The panel and AHCPR invited 155 outside reviewers to peer review the guideline draft. In addition, AHCPR placed a notice in the Federal Register inviting individuals to review and comment on the draft guideline. A total of 71 reviewers provided comments. Peer reviewers included clinicians, health care program directors, social workers, counselors, health educators, researchers with clinical experience, consumers, and key personnel at selected Federal agencies (CDC, National Institute on Drug Abuse, NCI, Food and Drug Administration [FDA]) among others. Reviewers were asked to evaluate the guideline based on five criteria: validity, reliability, clarity, clinical applicability, and utility. The reviewers were encouraged to provide additional comments. Comments of the peer reviewers were evaluated by the panel and panel staff and were incorporated into the guideline when appropriate.