# Contributors

This section acknowledges the numerous individuals who contributed their time and expertise to the development of this guideline. Contributors include panel members, consultants, panel staff, contractor support personnel, AHCPR personnel, and peer reviewers. Without their intense efforts and collaborative endeavors, this guideline would not have been possible.

## Cardiac Rehabilitation Guideline Panel

- Nanette Kass Wenger, MD
- Panel Co-Chair
- Professor of Medicine (Cardiology)
- Emory University School of Medicine
- Consultant, Emory Heart Center
- Atlanta, Georgia

Dr. Wenger is Professor of Medicine (Cardiology) at the Emory University School of Medicine, Director of Cardiac Clinics at Grady Memorial Hospital in Atlanta, Georgia, and Consultant to the Emory Heart Center. She is a graduate of the Harvard Medical School and was trained in Internal Medicine and Cardiology at the Mount Sinai Hospital in New York and at the Emory University School of Medicine. Dr. Wenger is a Fellow of the American College of Cardiology, the American College of Physicians, the American College of Chest Physicians, the American Association of Cardiovascular and Pulmonary Rehabilitation, and the Council on Geriatric Cardiology. She is a past president of the American Heart Association Georgia Affiliate, a past vice president of the American Heart Association and past secretary and member of the Board of Trustees of the American College of Cardiology. Dr. Wenger is also a past president of the Scientific Council on Rehabilitation of the International Society and Federation of Cardiology and recently chaired the World Health Organization Expert Committee on Rehabilitation after Cardiovascular Diseases. Dr. Wenger is currently president of the Council on Geriatric Cardiology and co-chair of the International Heart Failure Education Task Force. She has authored more than 750 scientific articles, book chapters, and textbooks.

- Erika Sivarajan Froelicher, RN, PhD
- Panel Co-Chair
- Professor
- Department of Physiological Nursing School of Nursing and Adjunct Professor Department of Epidemiology and Biostatistics
- School of Medicine
- University of California, San Francisco
- San Francisco, California

Dr. Froelicher is a professor of Nursing and Epidemiology at UCSF. She is a graduate of the University of Washington, Seattle, School of Nursing, where she earned a Bachelor of Science in Nursing and a Master of Arts in Nursing (minor in Business Administration). Her master's in Public Health and doctorate in Public Health-Epidemiology (minor in Biostatistics) were earned at the University of California Los Angeles, School of Public Health. She has more than 20 years experience in clinical practice, teaching, and research related to the prevention and rehabilitation of cardiovascular disease. Dr. Froelicher is a fellow of the American Academy of Nursing, the American Heart Association-Council of Cardiovascular Nursing, and the American Association of Cardiovascular and Pulmonary Rehabilitation. She is one of 12 founding editorial board members of the Journal of Cardiac Rehabilitation. She serves on the editorial boards of Heart and Lung, American Journal of Critical Care, and Progress in Cardiovascular Nursing. She is a member of the American Heart Association Committee on Exercise and Rehabilitation and has served on the American College of Cardiology-Prevention Committee. Dr. Froelicher is currently a member of an Institute of Medicine Committee on the Adequacy of Nurse Staffing. She has served as a peer reviewer for the AHCPR Clinical Practice Guidelines Heart Failure: Evaluation and Care of Patients With Left-Ventricular Systolic Dysfunction and Unstable Angina: Diagnosis and Management and has participated in numerous AHCPR meetings to identify priorities for guideline development. Dr. Froelicher's program of research has focused on studying the efficacy of activity and exercise prescription, education, and counseling in patients with heart disease as well as risk factor reduction using education-counseling and behavioral interventions to reduce risk, improve adherence, and enhance quality of life. Dr. Froelicher has published extensively: textbook, chapters, scientific and professional articles on exercise testing, patient and family education, and counseling and behavioral interventions.

- L. Kent Smith, MD, MPH
- Project Director
- Director, Cardiac Rehabilitation
- Arizona Heart Institute
- Phoenix, Arizona

Dr. Smith received his medical training from Creighton University and was a resident in internal medicine at the Mayo Clinic prior to a cardiology fellowship with the Beth Israel Hospital in Boston. He was on the faculty at Boston University School of Medicine for 7 years, where he obtained his master's in public health. He is a founding fellow of the American Association of Cardiovascular and Pulmonary Rehabilitation, where he has served as president. Dr. Smith has written over 70 scientific articles and served as principal investigator in over 100 research trials. He is the scientific section editor of the Journal of Cardiopulmonary Rehabilitation.

- Philip A. Ades, MD
- Director, Cardiac Rehabilitation
- Associate Professor
- University of Vermont College of Medicine
- Burlington, Vermont

Dr. Ades is Director of Cardiac Rehabilitation and Associate Director of the Clinical Research Center at the University of Vermont College of Medicine. He is clinical editor of the Journal of Cardiopulmonary Rehabilitation and has written approximately 50 papers in the field of cardiac rehabilitation and exercise physiology.

- Kathy Berra, BSN
- Clinical Trials Director
- Stanford Center for Research in Disease Prevention
- Palo Alto, California

Ms. Berra is a clinical trial director at the Stanford Center for Research in Disease Prevention at Stanford University. She has authored many book chapters and articles on cardiac rehabilitation over the past 25 years. She serves on the editorial boards of the Journal of Cardiovascular and Pulmonary Rehabilitation, Heart and Lung, and Progress in Cardiovascular Nursing. She is past clinical editor of the Journal of Cardiovascular and Pulmonary Rehabilitation. She is a past president of the American Association of Cardiovascular and Pulmonary Rehabilitation and is a fellow on the Council on Cardiovascular Nursing of the American Heart Association.

- James A. Blumenthal, PhD
- Director, Behavioral Medicine Program Center for Living
- Duke University Medical Center
- Durham, North Carolina

Dr. Blumenthal is a Professor of Medical Psychology and an Assistant Professor of Medicine at Duke University Medical Center. He is also a Professor of Psychology in the Department of Psychology: Social and Health Sciences at Duke University. He helped to develop Duke University's Cardiac Rehabilitation Program ("Dupac") and contributed to the development of psychosocial guidelines for the North Carolina Cardiac Rehabilitation Certification Plan, which was adopted in 1979. Dr. Blumenthal is a fellow in the American Psychological Association in Divisions 38 (Health), 20 (Aging), and 12 (Clinical) and also holds fellowship status in the Society of Behavioral Medicine and the Academy of Behavioral Medicine Research. He is currently president-elect of the American Psychosomatic Society. He also is a founding fellow of the American Association of Cardiovascular and Pulmonary Rehabilitation and was the first psychologist on that organization's executive board. His research focuses on psychosocial factors and health and behavioral interventions in primary and secondary prevention of coronary heart disease. He has published over 150 articles, 34 book chapters, and co-edited three books.

- Catherine M. E. Certo, ScD, PT
- Associate Professor
- Boston University
- Sargent College of Allied Health Professions
- Boston, Massachusetts

Dr. Certo is Professor and Chairman of the Department of Physical Therapy at Boston University, Sargent College of Allied Health Professions. She has served as president of the American Physical Therapy Association's Cardiopulmonary Section and is also a member of the American College of Sports Medicine, the American Heart Association, the Massachusetts Society for Cardiac Rehabilitation, and the American Association of Cardiovascular and Pulmonary Rehabilitation. Dr. Certo has over 20 years experience in all phases of cardiac rehabilitation. She is a co-author of Clinical Medicine for Physical Therapy and has written over a dozen research articles on cardiopulmonary care.

- Anne M. Dattilo, PhD, RD
- Assistant Professor
- Department of Nutrition
- University of Georgia
- Athens, Georgia

Dr. Dattilo is a consulting dietitian specializing in cardiovascular nutrition. She provides consultation to professional groups and individuals about implementing clinical nutrition protocol and conducts research on the effectiveness of diet therapy on cardiovascular disease.

- Dwight Davis, MD
- Director, Cardiac Rehabilitation Program
- Professor of Medicine
- University Hospital
- The Milton S. Hershey Medical Center
- Hershey, Pennsylvania

Dr. Davis developed the Cardiac Rehabilitation Program at Penn State and serves as Cardiology Director of the University Hospital Fitness and Performance Testing Center. He has authored over 70 research publications. In his role as a member of the Cardiac Transplantation and Artificial Organs Program, he has a special interest in exercise in patients with ventricular assist devices and total artificial hearts.

- Robert F. DeBusk, MD
- Professor of Medicine
- Stanford University School of Medicine
- Palo Alto, California

Dr. DeBusk is Professor of Medicine (Cardiology) at the University School of Medicine and is founder and director of the Stanford Cardiac Rehabilitation Program. For more than 20 years he and his colleagues have carried out research evaluating prognosis, functional capacity, and psychological status of patients with coronary disease as the basis for treatment programs whose focus has been home-based risk factor management. More recently he and his colleagues have developed and evaluated a physician-supervised, nurse-directed case management system for coronary risk factors and chronic diseases including heart failure, diabetes, and hypertension. He is a fellow of the American College of Cardiology and the American College of Physicians. He has published more than 80 original research articles.

- Joseph P. Drozda, Jr., MD
- Chief of Cardiology and Medical Director of the Cardiac Rehabilitation Program
- DePaul Health Center
- St. Louis, Missouri

Dr. Drozda has been a practicing cardiologist in the St. Louis area for over 18 years. He started the cardiac rehabilitation program at the DePaul Health Center in 1982. In addition, he was one of a group of physicians who founded Physicians Health Plan of Greater St. Louis (an IPA model HMO) and served as medical director of that organization from 1987 through 1994. He is a frequent lecturer on the use of practice guidelines in the managed care setting.

- Barbara J. Fletcher, RN, MN
- Director of Research
- Emory Health Enhancement Program
- Emory University
- Atlanta, Georgia

Ms. Fletcher has been involved with cardiac rehabilitation for over 20 years and currently coordinates research activities in cardiac rehabilitation at Emory University. She has 30 publications in the field of cardiac rehabilitation in professional journals and recently co-authored the American Heart Association "Scientific Statement for Health Care Professionals for Cardiac Rehabilitation Programs." She has also authored five patient education booklets regarding heart disease and rehabilitation. She currently serves as Chair of the Council on Cardiovascular Nursing for the American Heart Association and holds appointments in the Nell Hodgson Woodruff School of Nursing, Emory University, and the Georgia State University School of Nursing.

- Barry A. Franklin, PhD
- Director, Cardiac Rehabilitation and Exercise Laboratories
- William Beaumont Hospital
- Royal Oak, Michigan

Dr. Franklin is editor-in-chief of the Journal of Cardiopulmonary Rehabilitation. He is a past president of the American Association of Cardiovascular and Pulmonary Rehabilitation and currently serves as president of the American Heart Association of Michigan. He holds editorial appointments on several scientific journals and has authored over 200 articles, research papers, books, and chapters.

- Helen Gaston (deceased)
- Tempe, Arizona

Ms. Gaston attended Fisk University and received her Bachelor of Arts from the University of Arizona and a master's degree from Arizona State University. She taught English in both the District of Columbia and Phoenix, Arizona. She developed a Black Studies Program for the Phoenix High School District in 1968.

- Philip Greenland, MD
- Harry W. Dingman Professor of Cardiology
- Chair, Department of Preventive Medicine
- Northwestern University Medical School
- Chicago, Illinois

Dr. Greenland is a cardiologist with primary interests in heart disease prevention and cardiac rehabilitation. He is Chairman and Professor of the Department of Preventive Medicine at Northwestern University Medical School and Medical Director of Cardiovascular Rehabilitation, Northwestern Memorial Hospital, Chicago. Dr. Greenland has authored or co-authored numerous research papers in various aspects of cardiology, preventive medicine, and cardiac rehabilitation. In 1988, he authored the cardiac rehabilitation guidelines for the American College of Physicians. He has recently been appointed Chairman, Committee on Preventive Cardiology, of the American Heart Association.

- Patrick E. McBride, MD, MPH
- Associate Professor
- Department of Family Medicine and Medicine-Cardiology
- University of Wisconsin-Madison
- Madison, Wisconsin

Dr. McBride has served as the co-director of the Preventive Cardiology Program at the University of Wisconsin since 1987. He is board certified in family practice and a member of the American Academy of Family Physicians. He has received his certification as an exercise program director from the American College of Sports Medicine. He is the past president of the American Society of Preventive Cardiology and has served on several guideline and expert panels related to cardiovascular disease prevention. He is the principal investigator for a large clinical trial, sponsored by the National Heart, Lung, and Blood Institute, which is testing methods to improve heart disease prevention services in primary care practices.

- Christopher G. A. McGregor, MB, FRCS
- Mayo Clinic
- Rochester, Minnesota

Dr. McGregor is a Professor of Surgery, Consultant in Thoracic and Cardiovascular Surgery, and Director of Cardiothoracic Transplantation at Mayo Medical Center in Rochester, Minnesota. He runs an active research laboratory and is medical director of the cardiac surgical and transplant unit at Saint Mary's Hospital, Rochester, Minnesota.

- Neil B. Oldridge, PhD
- Professor of Health Sciences
- University of Wisconsin-Milwaukee
- Milwaukee, Wisconsin

Dr. Oldridge is Professor of Health Sciences, University of Wisconsin, and Adjunct Professor of Health Services Research, Medical College of Wisconsin. He conducts grant-funded research on the effectiveness of rehabilitation for patients with coronary heart disease and for patients with low back pain with a special interest in health-related quality of life and cost effectiveness. He is past president of the American College of Sports Medicine and has served since 1987 as an ad hoc member of the Study Section for Epidemiology and Disease Control at the National Institutes of Health.

- Joseph C. Piscatella
- President
- Institute for Fitness and Health, Inc.
- Tacoma, Washington

Mr. Piscatella is a nationally known health educator. As one who experienced coronary bypass surgery at age 32 and coronary regression at age 47, he provides a unique perspective on the practical aspects of lifestyle habits and health. He lectures to a variety of clients including Fortune 500 companies, professional associations, and medical organizations. He has written four books, which are used by more than 5,500 hospitals in cardiac programs.

- Felix J. Rogers, DO
- Downriver Cardiology Consultants
- Trenton, Michigan

Dr. Rogers is a private practice cardiologist, working in an osteopathic community hospital. He participates in the supervision of a cardiac rehabilitation program in an office setting, including standard Phase II and Phase III cardiac exercise programs, for patients with congestive heart failure and a program for reversal of atherosclerosis. He is Clinical Professor of Internal Medicine at the Michigan State University College of Osteopathic Medicine and has an interest in the development of comprehensive treatment programs for heart failure and for preventive cardiology, to be applied in the private practice and community hospital setting.

## Peer Reviewers

Note: Being listed in this section does not necessarily imply endorsement of the guideline product.

- Alan Adelman, MD, MS
- Pennsylvania State University
- Hershey, Pennsylvania
- Linda S. Baas, PhD, RN, CCRN
- University of Cincinnati
- Cincinnati, Ohio
- Gary Balady, MD
- Boston University Medical Center
- Boston, Massachusetts
- Frank S. Becker, MD
- Northwestern University
- Chicago, Illinois
- Lawrence P. Cahalin, MA, PT
- Massachusetts General Hospital
- Boston, Massachusetts
- Donald E. Casey, Jr., MD
- Greater Baltimore Medical Center
- Baltimore, Maryland
- Lynda R. Costanzo, RN, MSN
- Social & Scientific Systems, Inc.
- Rockville, Maryland
- Charles Dennis, MD
- Deborah Heart & Lung Center
- Brown Mills, New Jersey
- Gerald Fletcher, MD
- Emory University
- Atlanta, Georgia
- Victor F. Froelicher, MD
- Stanford University School of Medicine
- Palo Alto, California
- Donna Frownfelter
- American Physical Therapy Association
- Glenview, Illinois
- Neil F. Gordon, MD, PhD, FACPM
- The Dallas Heart Group
- Dallas, Texas
- Cecelia Gatson Grindel, PhD, RN
- Lehigh Valley Hospital
- Allentown, Pennsylvania
- Linda Hall, PhD
- Human Kinetics Publishers
- Champaign, Illinois
- William Haskell, PhD
- Stanford Medical Center
- Palo Alto, California
- David L. Herbert, JD
- Herbert, Benson & Scott Attorneys at Law
- Canton, Ohio
- William Herbert, PhD
- Virginia Tech
- Blacksburg, Virginia
- Martha N. Hill, RN, PhD
- Johns Hopkins University School of Nursing
- Baltimore, Maryland
- Ellen A. Hillegass, MMSc, PT
- Georgia State University
- Atlanta, Georgia
- Robert R. Huhn, MA, PT
- Human Performance Center
- Santa Barbara, California
- Reed Humphrey, PhD, PT
- Virginia Commonwealth University
- Richmond, Virginia
- Nancy Huntley, BS, OTR
- American Occupational Therapy Association
- Golden Valley, Minnesota
- Scot Irwin
- Physiotherapy Associates
- Jonesboro, Georgia
- Louise Jenkins, PhD, RN
- University of Wisconsin School of Nursing
- Milwaukee, Wisconsin
- Andrea Legatt Kivolowitz
- Meriter Hospital
- Madison, Wisconsin
- Arthur S. Leon, MD, MS
- University of Minnesota
- Minneapolis, Minnesota
- Martha Livingston, BSN, MS, MBA
- Baptist Memorial Hospital
- Memphis, Tennessee
- Robert J. Luchi, MD
- Baylor College of Medicine
- Houston, Texas
- Timothy R. McConnell, PhD
- Geisinger Medical Center
- Danville, Pennsylvania
- William P. Marley, PhD
- Marshall University
- Huntington, West Virginia
- Sebastian A. Mazzotta, MD, FACG
- Canton-Potsdam Hospital
- Canton, New York
- Henry S. Miller, Jr., MD
- Bowman Gray School of Medicine
- Winston-Salem, North Carolina
- Nancy Houston-Miller, BSN
- Stanford University
- Palo Alto, California
- Carolyn Moore, PhD, RD
- The Methodist Hospital
- Houston, Texas
- Geoffrey E. Moore, MD
- University of Pittsburgh
- Pittsburgh, Pennsylvania
- Dean Ornish, MD
- Preventive Medicine Research Institute
- Sausalito, California
- Fredric J. Pashkow, MD
- Cleveland Clinic Foundation
- Cleveland, Ohio
- Peg Pashkow, MEd, PT
- The Rehabilitation Hospital at Heather Hill
- Chardon, Ohio
- Michael Pollock, PhD
- University of Florida
- Gainesville, Florida
- Nancy S. Redeker, PhD, MSN, RNC
- Rutgers-The State University of New Jersey
- Newark, New Jersey
- Barbara Riegel, DNSc, RN, CS, FAAN
- Sharp Healthcare
- San Diego, California
- Roger B. Rodrigue, MD, MPH
- American Academy of Family Practice
- Kansas City, Missouri
- Wayne M. Sotile, PhD
- Wake Forest University
- Winston-Salem, North Carolina
- Douglas R. Southard, PhD, MPH
- Virginia Tech
- Blacksburg, Virginia
- Ray W. Squires, PhD
- Mayo Clinic
- Rochester, Minnesota
- George E. Taffet, MD
- Baylor College of Medicine
- Houston, Texas
- C. Barr Taylor, MD
- Stanford Medical Center
- Stanford, California
- Steven Van Camp, MD
- Alvarado Hospital Medical Center
- San Diego, California
- Judith J. Warren, PhD, RN
- University of Nebraska Medical Center
- Omaha, Nebraska
- Kathy K. Warren, RD
- Eugene, Oregon
- Mark Williams, PhD
- Creighton University School of Medicine
- Omaha, Nebraska

## AHCPR Staff

- Douglas B. Kamerow, MD, MPH
- Director
- Office of the Forum for Quality and Effectiveness in Health Care
- Carole Hudgings, PhD, RN
- Senior Health Policy Analyst
- Ernestine W. Murray, RN, MAS
- Panel Project Officer
- Margaret Rutherford
- Managing Editor
- Harriett V. Bennett
- Public Affairs Specialist

## NHLBI Staff

- George Sopko, MD, MPH
- Medical Officer/Cardiology Expert
- Division of Heart and Vascular Diseases
- National Heart, Lung, and Blood Institute
- National Institute of Health

## Contract Support

Technical Resources International, Inc. Rockville, MD

- Gail J. Herzenberg, MPA
- Project Director
- Marcia R. Feinleib
- Managing Editor
- Mark A. Meschter
- Production Manager
- Rafy Levy
- Cover Designer
- Carlos Gonzalez
- Book Designer