# Glossary

ACE inhibitor (angiotensin-converting enzyme inhibitor):: A category of drug used to treat high blood pressure and heart failure.

Acute myocardial infarction:: An event caused by death of heart muscle due to obstruction or blockage of a coronary artery.

Aerobic exercise:: Exercise characterized by repetitive movement of large muscle groups; the energy needed is supplied by inspired oxygen.

Aneurysm:: A sac formed by the dilatation of the wall of an artery, a vein, or a heart chamber.

Angina pectoris:: Pain or discomfort in the chest due to inadequacy of blood supply to meet oxygen demands of the myocardium, commonly precipitated by effort or emotion.

Angiographically significant CAD:: A 70 percent or greater diameter blockage of one or more major epicardial coronary artery segments or a 50-percent diameter stenosis of the left main coronary artery shown by x-ray examination after injection of fluid opaque to x-rays.

Arrhythmia:: Alteration of the normal rhythm of the heart; abnormal heart rhythm.

Atherosclerosis:: A common form of arteriosclerosis in which yellowish plaques (atheromas) containing cholesterol, lipoid material, and lipophages form within or beneath the intima of large- and medium-size arteries.

Behavioral intervention:: Systematic instruction in techniques to modify health-related behaviors.

Beta blocker (beta-adrenergic blocking agent):: A drug that antagonizes the effect of sympathetic stimulation, producing a decrease in heart rate, blood pressure, myocardial contractility, and stroke volume, and thereby lessens oxygen demand in the myocardium and decreases angina pectoris.

Blood pressure:: The driving force that moves blood through the circulatory system. Systolic blood pressure is the blood pressure when the ventricular muscle contracts. Diastolic blood pressure is blood pressure when the ventricular muscle is relaxed between beats.

Cardiac catheterization:: Passage of a catheter into the heart through a vein or artery, under x-ray control, used to diagnose cardiac abnormalities.

Cardiac mortality:: Death due to disease of the heart.

Cardiomyopathy:: Primary heart muscle disease, often of obscure or unknown etiology, unassociated with coronary disease, hypertension, valve disease, and so on.

Cholesterol:: A lipid or fatty substance found in tissues or blood. Elevated levels in the blood predispose to atherosclerosis in the coronary and other arteries.

Comorbidity:: A concomitant but unrelated disease, usually used to indicate coexistence of two or more disease processes.

Coronary angiography:: A diagnostic technique that involves the injection of fluid opaque to x-rays into the coronary arteries and heart chambers.

Coronary artery bypass graft surgery (CABG):: Bypass of an obstructed coronary artery using an artery in the chest or a vein segment from the leg attached to the aorta.

Coronary artery disease (CAD):: A progressive atherosclerotic narrowing of the coronary arteries with resultant reduction in the blood and oxygen supply to the heart muscle.

Coronary heart disease (CHD):: Heart disease resulting from atherosclerotic coronary artery obstruction (CAD).

Counseling:: Providing advice, support, and consultation.

Dyspnea:: Difficult or labored breathing.

Echocardiography:: Use of ultrasound to detect and record intracardiac structures and their motion and measure cardiac chamber size, shape, and wall thickness.

Education:: Systematic instruction.

Ejection fraction:: A measure of pumping action of the left ventricle of the heart, normally 65 +/- 8 percent; lower values indicate ventricular dysfunction. The difference between left ventricular end diastolic volume and left ventricular end systolic volume divided by left ventricular end diastolic volume.

Electrocardiogram:: A graphic record of the electrical activity of the heart, obtained with an electrocardiograph. Also called an "ECG" or "EKG."

Ergometer:: An apparatus -- such as a treadmill, stationary bicycle, or steps -- used to measure the physiologic effects of exercise.

Ergometry:: Measurement of the physiologic effects of exercise, using standard equipment.

Exercise test:: A diagnostic test in which the patient exercises on a treadmill, bicycle, or other equipment with ECG and blood pressure monitoring, also referred to as a stress test.

Fibrillation:: Chaotic rapid contraction or twitching of atrial or ventricular muscle.

Heart failure:: Failure of the heart to maintain adequate flow of blood to the tissues.

Heart rate:: Number of beats of the heart per minute.

High-density lipoprotein:: A complex of lipid and protein molecules to transport cholesterol, also called "HDL." The cholesterol component that transports cholesterol to the liver for metabolism.

Hypercholesterolemia:: Excess cholesterol level in the blood.

Hyperlipidemia:: Abnormally high concentration of any lipid in the blood.

Hypertension:: Elevation of arterial blood pressure above normal range. Commonly called high blood pressure.

Hypotension:: Abnormally low blood pressure.

Left ventricular function:: Pumping function of the chamber supplying body circulation.

Lipid:: Any of a variety of fat and fat-like substances characterized by being water-insoluble.

Lipoprotein:: A complex of lipid and protein molecules that transports lipids, primarily cholesterol and triglycerides, from one organ to another; LDL and HDL are lipoproteins.

Low-density lipoprotein:: A complex of lipid and protein molecules to transport cholesterol, also called "LDL." The cholesterol component that transports cholesterol from the liver to the rest of the body.

MET (metabolic equivalent unit):: A resting metabolic unit, the equivalent of 1.2 calories per minute or 3.5-4.0 mL/kg/min; 1 MET equals the amount of energy expended at rest.

Multidisciplinary:: Of, pertaining to, or arising through the action of many disciplines or professions.

Myocardial ischemia:: Deficiency of blood supply to heart muscle.

Percutaneous transluminal coronary angioplasty (PTCA):: An invasive procedure to enlarge the lumen of a narrowed coronary artery by balloon compression. The angioplasty catheter is inserted into a coronary artery, and the balloon is inflated at the site of an obstructing atheroma.

Radionuclide ventriculography:: Assessment of cardiac chamber size and performance by intravenous radioisotope injection.

Rate-pressure product:: Heart rate multiplied by the systolic blood pressure; an index of myocardial oxygen requirement.

Resuscitation:: The restoration to life or consciousness of an individual showing no signs of life; it includes such measures as artificial respiration and cardiac massage.

Restenosis:: Stenosis, or narrowing, of an artery recurring after correction of the blockage.

Revascularization:: The restoration of adequate blood supply, usually to heart muscle; CABG and PTCA are techniques of myocardial revascularization.

Risk factors:: Characteristics associated with an increased rate of a subsequently occurring disease.

ST-segment displacement:: Abnormality of repolarization evident on the ECG, important in detecting myocardial ischemia at exercise testing.

Streptokinase:: A drug that can dissolve blood clots, used to open obstructed coronary arteries in the early hours following myocardial infarction.

Tachycardia:: Abnormally fast heart rate, > 100 beats per minute.

Target heart rate:: Goal heart rate for exercise training; often 60-85 percent of the symptom-limited heart rate at prior exercise testing.

Thrombolytic therapy:: Pharmacologic agents designed to dissolve blood clots formed within the vascular system.

t-PA (tissue-type plasminogen activator):: A drug used to dissolve blood clots in an obstructed coronary artery in the early hours following myocardial infarction.

Triglycerides:: A triester of glycerol with one, two, or three acid molecules.

Unstable angina:: Chest pain of myocardial ischemia that occurs at rest, new onset of pain with exertion, or pain that has accelerated (more frequent, longer in duration, or lower in threshold).

Ventricular dysfunction:: Abnormality of the pumping function of the ventricle.