# Acronyms

AACVPR: American Association of Cardiovascular and Pulmonary Rehabilitation

ACC: American College of Cardiology

ACP: American College of Physicians

ACSM : American College of Sports Medicine

AHA : American Heart Association

AHCPR: Agency for Health Care Policy and Research

bpm : Beats per minute

CABG: Coronary artery bypass graft surgery

CAD : Coronary artery disease

CHD: Coronary heart disease

ECG : Electrocardiogram, electrocardiographic

EF : Ejection fraction

GUSTO : Global Utilization of Streptokinase and t-PA for Occluded Coronary Arteries Trial

HDL : High-density lipoprotein

JNC V : The Fifth Report of the Joint National Committee on Detection, Evaluation and Treatment of High Blood Pressure

LDL: Low-density lipoprotein

LV : Left ventricle, left ventricular

MET: Metabolic equivalent unit

MI : Myocardial infarction

MMPI : Minnesota Multiphasic Personality Inventory

NCEP II: The Second Report of the Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel)

NHLBI : National Heart, Lung, and Blood Institute

NIH : National Institutes of Health

PTCA : Percutaneous transluminal coronary angioplasty

RCT : Randomized clinical trial

SES: Socioeconomic status

WCGS: Western Collaborative Group Study

WHO: World Health Organization