# References

Ades PA, Grunvald MH. Cardiopulmonary exercise testing before and after conditioning in older coronary patients. Am Heart J. 1990;120:585-9. [pmid: 2389695].
Ades PA, Hanson JS, Gunther PG, Tonino RP. Exercise conditioning in the elderly coronary patient. J Am Geriatr Soc. 1987;35:121-4. [pmid: 3805554].
Ades PA, Huang D, Weaver SO. Cardiac rehabilitation participation predicts lower rehospitalization costs. Am Heart J. 1992;123:916-21. [pmid: 1550000].
Ades PA, Waldmann ML, Gillespie C. A controlled trial of exercise training in older coronary patients. J Gerontol. 1995;50A:M7-11.
Ades PA, Waldmann ML, Poehlman ET, Gray P, Horton ED, Horton ES, LeWinter MM. Exercise conditioning in older coronary patients: submaximal lactate response and endurance capacity. Circulation. 1993;88:572-7. [pmid: 8339420].
Ades PA, Waldmann ML, Polk D, Coflesky JT. Referral patterns and exercise response in the rehabilitation of female coronary patients aged ≥62 years. Am J Cardiol. 1992;69:1422-5. [pmid: 1590231].
Adsett CA, Bruhn JG. Short-term group psychotherapy for post-myocardial infarction patients and their wives. Can Med Assoc J. 1968;99:577-84. [pmid: 4386800]. [pmcid: 1945281].
Agency for Health Care Policy and Research. Cardiac rehabilitation programs Health technology assessment reports, 1991, no. 3. DHHS publication no. AHCPR 92-0015, Rockville, MD: Agency for Health Care Policy and Research, Public Health Service, U.S. Department of Health and Human Services. Dec 1991
Ahern DK, Gorkin L, Anderson JL, Tierney C, Hallstrom A, Ewart C, Capone RJ, Schron E, Kornfeld D, Herd JA, et al. Biobehavioral variables and mortality or cardiac arrest in the Cardiac Arrhythmia Pilot Study (CAPS). Am J Cardiol. 1990;66:59-62. [pmid: 2193497].
American Association of Cardiovascular and Pulmonary Rehabilitation. Guidelines for cardiac rehabilitation programs, Champaign (IL):Human Kinetics Books;1991
American Association of Cardiovascular and Pulmonary Rehabilitation. Guidelines for cardiac rehabilitation programs 2nd ed, Champaign (IL): Human Kinetics Books; 1995
American College of Physicians, Health and [Public] Policy Committee. Cardiac rehabilitation services [position paper]. Ann Intern Med. 1988;109:671-3. [pmid: 3421577].
American College of Sports Medicine, Preventative and Rehabilitative Exercise Committee. Guidelines for exercise testing and prescription 4th ed, Philadelphia:Lea & Febiger;1991
American Heart Association. Exercise standards: a statement for health professionals from the American Heart Association [special report]. Circulation. 1990;82:2286-322. [pmid: 2242557].
American Heart Association. Statement on exercise: benefits and recommendations for physical activity programs for all Americans; a statement for health professionals by the committee on exercise and cardiac rehabilitation of the Council on Clinical Cardiology, American Heart Association [position statement]. Circulation. 1992;86:340-4. [pmid: 1617788].
American Heart Association. Cardiac rehabilitation programs: a statement for health care professionals from the American Heart Association [position statement]. Circulation. 1994;90:1602-10. [pmid: 8087975].
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders 3rd ed., rev. (DSM-III-R), Washington, DC: authors 1987
Amos KR, Porcari JP, Bauer SR, Wilson PK. The safety and effectiveness of walking with ankle weights and wrist weights for patients with cardiac disease. J Cardiopulm Rehabil. 1992;12:254-60.
Andrew GM, Oldridge NB, Parker JO, Cunningham DA, Rechnitzer PA, Jones NL, Buck C, Kavanagh T, Shephard RJ, Sutton JR, et al. Reasons for dropout from exercise programs in post-coronary patients Med Sci Sports Exerc 1981 13(3):164 8 7253867
Appels A. Psychological prodromata of myocardial infarction and sudden death. Psychosom Res. 1980;34:187-95.
Appels A. Mental precursors of myocardial infarction. Br J Psychiatry. 1990;156:465-71. [pmid: 1974819].
Appels A, Mulder P. Excess fatigue as a precursor of myocardial infarction Eur Heart J 1988 Jul 9(7):758 64 3169045
Appels A, Mulder P. Fatigue and heart disease: the association between `vital exhaustion' and past, present and future coronary heart disease J Psychosom Res 1989 33(6):727 38 2621676
Arvan S. Exercise performance of the high risk acute myocardial infarction patient after cardiac rehabilitation. Am J Cardiol. 1988;62:197-201. [pmid: 3400598].
Bar FW, Hoppener P, Diederiks J, Voken H, Bekkers J, Hoofd W, Appels A, Wellins HJ. Cardiac rehabilitation contributes to the restoration of leisure and social activities after myocardial infarction. J Cardiopulm Rehabil. 1992;12:117-25.
Barefoot JC, Dahlstrom WG, Williams RB Jr. Hostility, CHD incidence, and total mortality: a 25-year follow-up study of 255 physicians. Psychosom Med. 1983;45:59-63. [pmid: 6844529].
Barletta GA, Fattirolli F, Bisi G, Bertini G, Malfanti PL, Gallini C, Pedenovi P, Fantini F. Short-term responses to cardiac rehabilitation after acute myocardial infarction: cardiac function evaluation before and after physical training at rest and during stress test Eur Heart J 1983 Nov 4(11):761 72 6653588
Barnard ND, Scherwitz LW, Ornish D. Adherence and acceptability of a low-fat, vegetarian diet among patients with cardiac disease. J Cardiopulm Rehabil. 1992;12:423-31.
Becker MH. Theoretical models of adherence and strategies for improving adherence: In: Shumaker SA, Schron EB, Ockene JK, senior editors; Parker CT, Probstfield JL, Wolle JM, co-editors. The handbook of health behavior changes, New York:Springer;1990. p. 5 43
Beckie T. A supportive-educative telephone program: impact on knowledge and anxiety after coronary artery bypass graft surgery. Heart Lung. 1989;18:46-55. [pmid: 2783580].
Ben-Ari E, Kellermann JJ, Fisman EZ, Pines A, Peled B, Drory Y. Benefits of long-term physical training in patients after coronary artery bypass grafting—a 58-month follow-up and comparison with a nontrained group. J Cardiopulm Rehabil. 1986;6:165-70.
Ben-Ari E, Rothbaum DA, Linnemeir TJ, Landin RJ, Steinmetz EF, Hillis SJ, Noble JR, Hallam CC, See MR, Shiner R. Benefits of a monitored rehabilitation program versus physician care after emergency percutaneous transluminal coronary angioplasty: follow-up of risk factors and rate of restenosis. J Cardiopulm Rehabil. 1989;7:281-5.
Ben-Ari E, Rothbaum DA, Linnemeier TA, Landin R, Tavel M, Steinmetz EF, Hillis JS, Hallam CC, Noble RJ, See MR, et al. Return to work after successful coronary angioplasty: comparison between a comprehensive rehabilitation program and patients receiving usual care. J Cardiopulm Rehabil. 1992;12:20-4.
Bengtsson K. Rehabilitation after myocardial infarction: a controlled study. Scand J Rehabil Med. 1983;15:1-9. [pmid: 6828827].
Beta-Blocker Heart Attack Trial Research Group. A randomized trial of propranolol in patients with acute myocardial infarction: I. mortality results. JAMA. 1982;247:1707-14. [pmid: 7038157].
Bilodeau CB, Hackett TP. Issues raised in a group setting by patients recovering from myocardial infarction Am J Psychiatry 1971 Jul 128(1):73 8 4345518
Blair SN, Kohl HW 3d, Paffenbarger RS Jr, Clark DG, Cooper KH, Gibbons LW. Physical fitness and all-cause mortality: a prospective study of healthy men and women. JAMA. 1989;262:239 5-401. [pmid: 2795824].
Blankenhorn DH, Nessim SA, Johnson RL, Sanmarco ME, Azen SP, Cashin-Hemphill L. Beneficial effects of combined colestipol-niacin therapy on coronary atherosclerosis and coronary venous bypass grafts. JAMA. 1987;257:3233-40. [pmid: 3295315].
Blumenthal JA, Califf R, Williams RS, Hindman M. Continuing medical education cardiac rehabilitation: new frontier for behavioral medicine. J Cardiopulm Rehabil. 1983;3:637-56.
Blumenthal JA, Emery CF, Rejeski WJ. The effects of exercise training on psychosocial functioning after myocardial infarction. J Cardiopulm Rehabil. 1988;8:183-93.
Blumenthal JA, Rejeski WJ, Walsh-Riddle M, Emery CF, Miller H, Roark S, Ribisl PM, Morris PB, Brubaker P, Williams RS. Comparison of high- and low-intensity exercise training early after acute myocardial infarction. Am J Cardiol. 1988;61:26-30. [pmid: 3337013].
Bohachick P. Progressive relaxation training in cardiac rehabilitation: effect on psychologic variables Nurs Res 1984 Sept-Oct 33(5):283 7 6382173
Bondestam E, Breikss A, Hartford M. Effects of early rehabilitation on consumption of medical care during the first year after acute myocardial infarction in patients ≥ 65 years of age. Am J Cardiol. 1995;75:767-71. [pmid: 7717276].
Boulay FM, David PP, Bourassa MG. Strategies for improving the work status of patients after coronary artery bypass surgery Circulation 1982 Nov 66(5 Pt 2):III43 49 6982123
Braun KL, Parcels JA, Brooks CJ, Knoll SF. Comparison of patient outcomes among early and late admissions to cardiac rehabilitation. J Cardiopulm Rehabil. 1989;9:72-9.
Brown G, Albers JJ, Fisher LD, Schaefer SM, Lin JT, Kaplan C, Zhao XQ, Bisson BD, Fitzpatrick VF, Dodge HT. Regression of coronary artery disease as a result of intensive or lipid-lowering therapy in men with high levels of apolipoprotein B. N Engl J Med. 1990;323:1289-98. [pmid: 2215615].
Brownell KD, Jeffery RW. Improving long-term weight loss: pushing the limits of treatment. Behav Ther. 1987;18:353-74.
Buchwald H, Varco RL, Matts JP, Long JM, Fitch LL, Campbell GS, Pearce MB, Yellin AE, Edmiston WA, Smink RD Jr, et al. Effect of partial ileal bypass surgery on mortality and morbidity from coronary heart disease in patients with hypercholesterolemia: report of the Program on the Surgical Control of the Hyperlipidemias (POSCH). N Engl J Med. 1990;325:946-55. [pmid: 2205799].
Burgess AW, Lerner DJ, D'Agostino RB, Vokonas PS, Hartman CR, Gaccione P. A randomized control trial of cardiac rehabilitation Soc Sci Med 1987 24(4):359 70 3551088
Burns PR, Bogenhagen W, Dykstra S, Einerson J, Parks B, Pease MO, Hanson P. Evaluation of exercise tapes in patients with cardiac disease. J Cardiopulm Rehabil. 1991;11:176-81.
Butler RM, Beierwaltes WH, Rogers FJ. The cardiovascular response to circuit weight training in patients with cardiac disease. J Cardiopulm Rehabil. 1987;7:402-9.
Butler RM, Palmer G, Rogers FJ. Circuit weight training in early cardiac rehabilitation J Am Osteopath Assoc 1992 Jan 92(1):77 89 1559860
Cannistra LB, Balady GJ, O'Malley CJ, Weiner DA, Ryan TJ. Comparison of the clinical profile and outcome of women and men in cardiac rehabilitation. Am J Cardiol. 1992;69:1274-9. [pmid: 1585859].
Cardus D, McTaggart WG, Ribas-Cardus F. Exercise training in ischemic heart disease: effect on physical performance and plasma lipids, ACTH, and cortisol Arch Phys Med Rehabil 1980 Jul 61(7):303 10 6249235
Carson P, Phillips R, Lloyd M, Tucker H, Neophytou M, Buch NJ, Gelson A, Lawton A, Simpson T. Exercise after myocardial infarction: a controlled trial. J R Coll Physicians Lond. 1982 July;16:147-51. [pmid: 7050369].
Case RB, Heller SS, Case NB, Moss AJ (The Multicenter Post-Infarction Research Group). Type A behavior and survival after acute myocardial infarction. N Engl J Med. 1985;312:737-41. [pmid: 3974650].
Centers for Disease Control and Prevention, Office on Smoking and Health. Public health focus: effectiveness of smoking-control strategies—United States. JAMA. 1992;268:1645-6. [pmid: 1527864].
Coats AJ, Adamopoulos S, Meyer TE, Conway J, Sleight P. Effects of physical training in chronic heart failure. Lancet. 1990;335:63-6. [pmid: 1967416].
Cohen S, Lichenstein E, Prochaska JO, Rossi JS, Gritz ER, Carr CR, Orleans CT, Schoenbach VJ, Biener L, Abrams D, et al. Debunking myths about self-quitting: evidence from 10 prospective studies of persons who attempt to quit smoking by themselves. Am Psychol. 1989;44:1355-65. [pmid: 2589730].
Coronary Drug Project Research Group. Influence of adherence to treatment and response of cholesterol on mortality in the Coronary Drug Project. N Engl J Med. 1980;303:1038-41. [pmid: 6999345].
Cowan GO. Influence of exercise on high-density lipoproteins. Am J Cardiol. 1983 Aug 22;52:13b-16b. [pmid: 6613860].
Cowan MJ. Cardiovascular nursing research. Annu Rev Nurs Res. 1990;8:3-33. [pmid: 2206628].
Crosby L, Paternostro-Bayles M, Cottington E, Pifalo WB. Outpatient rehabilitation after right ventricular infarction. J Cardiopulm Rehabil. 1989;7:286-91.
Crozier Ghilarducci LE, Holly RG, Amsterdam EA. Effects of high resistance training in coronary artery disease. Am J Cardiol. 1989;64:866-70. [pmid: 2801553].
Daltroy LH. Improving cardiac patient adherence to exercise regimens: a clinical trial of health education. J Cardiopulm Rehabil. 1985;5:40-9.
Dattilo AM, Kris-Etherton PM. Effects of weight reduction on blood lipids and lipoprotein: a meta-analysis. Am J Clin Nutr. 1992;56:320-8. [pmid: 1386186].
Daumer R, Miller P. Effects of cardiac rehabilitation on psychosocial functioning and life satisfaction of coronary artery disease clients Rehabil Nurs 1992 Mar-Apr 17(2):69 72 1553419
DeBusk RF, Blomqvist CG, Kouchoukos NT, Luepker RV, Miller HS, Moss AJ, Pollock ML, Reeves TJ, Selvester RH, Stason WB, et al. Identification and treatment of low-risk patients after acute myocardial infarction and coronary-artery bypass graft surgery. N Engl J Med. 1986;314:161-6. [pmid: 3510385].
DeBusk RF, Haskell WL, Miller NH, Berra K, Taylor CB, Berger WE 3d, Lew H. Medically directed at-home rehabilitation soon after [clinically] uncomplicated acute myocardial infarction: a new model for patient care Am J Cardiol 1985 55(4):251 7 3969859
DeBusk RF, Houston N, Haskell W, Fry F, Parker M. Exercise training soon after myocardial infarction. Am J Cardiol. 1979;44:1223-9. [pmid: 506925].
DeBusk RF, Houston Miller N, Superko HR, Dennis CA, Thomas RJ, Lew HT, Berger WE 3d, Heller RS, Rompf J, Gee D, et al. A case-management system for coronary risk factor modification after acute myocardial infarction. Ann Intern Med. 1994;120:721-9. [pmid: 8147544].
Delbanco TL. Enriching the doctor-patient relationship by inviting the patient's perspective. Ann Intern Med. 1992;116:414-8. [pmid: 1736775].
Dennis C, Houston-Miller N, Schwartz RG, Ahn DK, Kraemer HC, Gossard D, Juneau M, Taylor CB, DeBusk RF. Early return to work after uncomplicated myocardial infarction: results of a randomized trial. JAMA. 1988;260:214-20. [pmid: 3385897].
Denollet J. Emotional distress and fatigue in coronary heart disease: the Global Mood Scale (GMS). Psychol Med. 1993a;23:111-21. [pmid: 8475198].
Denollet J. Sensitivity of outcome assessment in cardiac rehabilitation J Consult Clin Psychol 1993b 61(4):686 95 8370865
Donavan JL, Donovan JL, Blake DR. Patient non-compliance: deviance or reasoned decision-making?. Soc Sci Med. 1992;34:507-13. [pmid: 1604357].
Dracup K. A controlled trial of couples group counseling in cardiac rehabilitation. J Cardiopulm Rehabil. 1985;5:436-42.
Dracup K. Cardiac rehabilitation: the role of social support in recovery and compliance: In: Shumaker SA, Czajkowski SM, editors. Social support and cardiovascular disease, New York: Plenum; 1994 p. 333 53
Dracup K, Meleis AI, Clark S, Clyburn A, Shields L, Staley M. Group counseling in cardiac rehabilitation: effect on patient compliance Patient Educ Couns 1984 6(4):169 77 10269521
Dressendorfer RH, Franklin BA, Smith JL, Hollingsworth V, DeWitt C, Cameron J, Borysyk LM, Gordon S, Timmis GC. Early cardiac rehabilitation training heart rate based on low-level treadmill testing after myocardial infarction and before hospital discharge. J Cardiopulm Rehabil. 1993;13:194-200.
Dressendorfer RH, Smith JL, Hollingsworth V, Trahan KJ, Ciske PE, Borysyk LM, Gordon S, Timmis GC. Propranolol treatment and the effectiveness of exercise training soon after myocardial infarction in patients not limited by exertional symptoms: improved maximal oxygen uptake and high-density lipoprotein cholesterol. J Cardiopulm Rehabil. 1990;10:409-17.
Dunbar JM, Marshall GD, Novell MF. Behavioral strategies for improving compliance: In: Haynes RB, Taylor DW, Sachett DL, editors. Compliance in health care, Baltimore: Johns Hopkins University Press;1979 p. 174 92
Dunbar-Jacob J, Dwyer K, Dunning EJ. Compliance with antihypertensive regimen: a review of research in the 1980s. Ann Behav Med. 1991;13:31-9.
Ehrman J, Keteyian S, Fedel F, Rhoads K, Levine B, Shephard R. Ventilatory threshold after exercise training in orthotopic heart transplant recipients. J Cardiopulm Rehabil. 1992;12:126-30.
Ehsani AA, Heath GW, Hagberg JM, Sobel BE, Holloszy JO. Effects of 12 months of intense exercise training on ischemic ST-segment depression in patients with coronary artery disease Circulation 1981 Dec 64(6):1116 24 7296787
Ehsani AA, Martin WH 3d, Heath GW, Coyle EF. Cardiac effects of prolonged and intense exercise training in patients with coronary artery disease Am J Cardiol 1982 Aug 50(2):246 54 7102557
Engblom E, Hietanen EK, Hamalainen H, Kallio V, Inberg M, Knuts LR. Exercise habits and physical performance during comprehensive rehabilitation after coronary artery bypass surgery Eur Heart J 1992 Aug 13(8):1053 9 1505554
Engblom E, Ronnemaa T, Hamalainen H, Kallio V, Vanttinen E, Knuts LR. Coronary heart disease risk factors before and after bypass surgery: results of a controlled trial on multifactorial rehabilitation Eur Heart J 1992 Feb 13(2):232 7 1348226
Epstein LH, Cluss PA. A behavioral medicine perspective on adherence to long-term medical regimens J Consult Clin Psychol 1982 Dec 50(6):950 71 6816844
Erdman RA, Duivenvoorden HJ, Verhage F, Kazemier M, Hugenholtz PG. Predictability of beneficial effects in cardiac rehabilitation: a randomized clinical trial of psychosocial variables. J Cardiopulm Rehabil. 1986;6:206-13.
Ewart CK, Stewart KJ, Gillilan RE, Kelemen MH. Self-efficacy mediates strength gains during circuit weight training in men with coronary artery disease Med Sci Sports Exerc 1986 18(5):531 40 3773670
Fagan ET, Wayne VS, McConachy DL. Serious ventricular arrhythmias in a cardiac rehabilitation programme. Med J Aust. 1984;141:421-4. [pmid: 6332265].
Faigenbaum AD, Skrinar GS, Cesare WF, Kraemer WJ, Thomas HE. Physiologic and symptomatic responses of cardiac patients to resistance exercise Arch Phys Med Rehabil 1990 May 71(6):395 8 2334283
Featherstone JF, Holly RG, Amsterdam EA. Physiologic responses to weight lifting in coronary artery disease. Am J Cardiol. 1993;71:287-92. [pmid: 8427169].
Feigenbaum E, Carter E. Cardiac rehabilitation services Health technology assessment report, 1987, no 6. DHHS publication no. PHS 88-3427, Rockville, MD: National Center for Health Services Research and Health Care Technology Assessment, Public Health Service, U.S. Department of Health and Human Services.Aug. 1988
Ferguson RJ, Petitclerc R, Choquette G, Chaniotis L, Gauthier P, Huot R, Allard C, Jankowski L, Campeau L. Effect of physical training on treadmill exercise capacity, collateral circulation and progression of coronary disease Am J Cardiol 1974 Dec 34(7):764 9 4432806
Fiatarone MA, Marks EC, Ryan, ND, Meredith CN, Lipsitz LA, Evans WJ. High-intensity strength training in nonagenarians: effects on skeletal muscle. JAMA. 1990;263:3029-34. [pmid: 2342214].
Fiore MC, Novotny TE, Pierce JP, Giovino GA, Hatziandreu EJ, Newcomb PA, Surawicz TS, Davis RM. Methods used to quit smoking in the United States: do cessation programs help?. JAMA. 1990;263:2760-5. [pmid: 2271019].
Fioretti P, Baardman T, Deckers J, Salm E, Zwiers F, Kazemier M, Roelandt J. Social fate and long-term survival of patients with a recent myocardial infarction, after cardiac rehabilitation Eur Heart J 1988 9(Suppl L):89 94 3243303
Fletcher GF. Rehabilitation after coronary angioplasty—is it effective? Arch Phys Med Rehabil 1986 Aug 67(8):517 9 2943252
Fletcher GF, Cantwell JD, Watt EW. Oxygen consumption and hemodynamic response of exercises used in training of patients with recent myocardial infarction Circulation 1979 July 60(1):140 4 445716
Fletcher GF, Chiaramida AJ, LeMay MR, Johnston BL, Thiel JE, Spratlin MC. Telephonically-monitored home exercise early after coronary artery bypass surgery Chest 1984 Aug 86(2):198 202 6611245
Fletcher BJ, Dunbar SB, Felner JM, Jensen BE, Almon L, Cotsonis G, Fletcher GF. Exercise testing and training in physically disabled men with clinical evidence of coronary artery disease. Am J Cardiol. 1994;73:170-4. [pmid: 8296738].
Foley JL, Sivarajan ES, Woods NF. Differences between men and women in recovery from myocardial infarction [abstract] Circulation 1983 68(Suppl III):
Foster C, Pollock ML, Anholm JD, Squires RW, Ward A, Dymond DS, Rod JL, Saichek RP, Schmidt DH. Work capacity and left ventricular function during rehabilitation after myocardial revascularization surgery Circulation 1984 Apr 69(4):748 55 6365351
Frasure-Smith N, Lesperance F, Talajic M. Depression following myocardial infarction: impact on 6-month survival. JAMA. 1993;270:1819-25. [pmid: 8411525].
Frasure-Smith N, Lesperance F, Talajic M. Depression and 18-month prognosis after myocardial infarction. Circulation. 1995;91:999-1005. [pmid: 7531624].
Frasure-Smith N, Prince R. The ischemic heart disease life stress monitoring program: impact on mortality Psychosom Med 1985 Sept-Oct 47(5):431 45 4059478
Frasure-Smith N, Prince R. Long-term follow-up of the Ischemic Heart Disease Life Stress Monitoring Program. Psychosom Med. 1989;51:485-513. [pmid: 2798700].
Friedman HS, DiMatteo MR. Patient-physician interactions. : The handbook of health behavior changes In: Shumaker SA, Schron EB, Ockene JK, senior editors; Parker CT, Probstfield JL, Wolle JM, co-editors, New York:Springer;1990 p. 85 101
Friedman M, Thoreson CE, Gill JJ, Ulmer D, Powell LH, Price VA, Brown B, Thompson L, Rabin DD, Breal WS, et al. Alteration of type A behavior and its effect on cardiac recurrences in post myocardial infarction patients: summary results of the Recurrent Coronary Prevention Project. Am Heart J. 1986;112:663-5. [pmid: 3766365].
Froelicher ES. Usefulness of [exercise] testing shortly after acute myocardial infarction for predicting 10-year mortality. Am J Cardiol. 1994;74:318-23. [pmid: 8059691].
Froelicher ES, Kee LL, Newton KM, Lindskog B, Livingston M. Return to work, sexual activity, and other activities after acute myocardial infarction Heart Lung 1994 Sept-Oct 23(5):423 35 7989211
Froelicher V, Jensen D, Genter F, Sullivan M, McKirnan MD, Witztum K, Sharf J, Strong ML, Ashburn W. A randomized trial of exercise training in patients with coronary heart disease JAMA 1984 Sept 14 252(10):1291 7 6381770
Fuster V, Badimon L, Badimon JJ, Chesebro JH. The pathogenesis of coronary artery disease and the acute coronary syndromes (2). N Engl J Med. 1992;326:310-8. [pmid: 1728735].
Garrity TF, Klein RF. Emotional response and clinical severity as early determinants of six-month mortality after myocardial infarction. Heart Lung. 1975;4:730-7. [pmid: 1041579].
Giannuzzi P, Tavazzi L, Temporelli PL, Corra U, Imparato A, Gattone M, Giordano A, Sala L, Schweiger C, Malinverni C. Long-term physical training and left ventricular remodeling after anterior myocardial infarction: results of the Exercise in Anterior Myocardial Infarction (EAMI) trial. J Am Coll Cardiol. 1993 Dec;22:1821-9. [pmid: 8245335].
Giannuzzi P, Temporelli PL, Tavazzi L, Corra U, Gattone M, Imparato A, Giordano A, Schweiger C, Sala L, Malinverni C, et al. EAMI—exercise training in anterior myocardial infarction: an ongoing multicenter randomized study; preliminary results on left ventricular function and remodeling Chest 1992 May 101(5 Suppl):315S 321S 1576857
Goble AJ, Hare DL, Macdonald PS, Oliver RG, Reid MA, Worcester MC. Effect of early programmes of high and low intensity exercise on physical performance after transmural acute myocardial infarction Br Heart J 1991 Mar 65(3):126 31 2015119 1024533
Godin G. The effectiveness of interventions in modifying behavioral risk factors of individuals with coronary heart disease. J Cardiopulm Rehabil. 1989;9:923-36.
Gorlin R. [Russek Lecture.] Must cardiology lose its heart?. J Am Coll Cardiol. 1992;19:1635-40. [pmid: 1593060].
Gould KL. Reversal of coronary atherosclerosis: clinical promise as a basis of noninvasive management of coronary artery disease Circulation 1994 90(3):1558 71 8087964
Grodzinski E, Jette M, Blumchen G, Borer JS. Effects of a four-week training program on left ventricular function as assessed by radionuclide ventriculography. J Cardiopulm Rehabil. 1987;7:518-24.
Gulanick M. Is phase 2 cardiac rehabilitation necessary for early recovery of patients with cardiac disease? A randomized, controlled study. Heart Lung. 1991;20:9-15. [pmid: 1988398].
Gutmann MC, Knapp DN, Pollock ML, Schmidt DH, Simon K, Walcott G. Coronary artery bypass patients and work status Circulation 1982 Nov 66(5 Pt 2):III33 42 6215187
Hakkila J. Morbidity and mortality after myocardial infarction. Bibl Cardiol. 1977; 1976;36:159-63. [pmid: 1029451].
Hamalainen H, Kallio V, Knuts LR, Arstila M, Aalto-Setala L, Harmala V, Kaarsalo E, Laurila S, Pere E. Community approach in rehabilitation and secondary prevention after acute myocardial infarction: results of a randomized clinical trial. J Cardiopulm Rehabil. 1991;11:221-6.
Hamalainen H, Luurila OJ, Kallio V, Arstila M, Hakkila J. Long-term reduction in sudden deaths after a multifactorial intervention programme in patients with myocardial infarction: 10-year results of a controlled investigation. Eur Heart J. 1989;10:55-62. [pmid: 2564823].
Hambrecht R, Niebauer J, Marburger C, Grunze M, Kalberer B, Hauer K, Schlierf G, Kubler W, Schuler G. Various intensities of leisure time physical activity in patients with coronary artery disease: effects on cardiorespiratory fitness and progression of coronary atherosclerotic lesions. J Am Coll Cardiol. 1993 Aug;22:468-77. [pmid: 8335816].
Hammond HK, Kelly TL, Froelicher VF, [Pewen] W. Use of clinical data in predicting improvement in exercise capacity after cardiac rehabilitation J Am Coll Cardiol 1985 July 6(1):19 26 4008773
Hands ME, Briffa T, Henderson K, Antico V, Thompson P, Hung J. Functional capacity and left ventricular function: the effect of supervised and unsupervised exercise rehabilitation soon after coronary artery bypass graft surgery. J Cardiopulm Rehabil. 1987;7:578-84.
Hartung GH, Rangel R. Exercise training in post-myocardial infarction patients: comparison of results with high risk coronary and post-bypass patients Arch Phys Med Rehabil 1981 62(4):147 50 6972205
Haskell WL. Cardiovascular complications during exercise training of cardiac patients Circulation 1978 May 57(5):920 4 639213
Haskell WL, Alderman EL, Fair JM, Maron DJ, Mackey SF, Superko HR, Williams PT, Johnstone IM, Champagne ME, Krauss RM, et al. Effects of intensive multiple risk factor reduction on coronary atherosclerosis and clinical cardiac events in men and women with coronary artery disease: The Stanford Coronary Risk Intervention Project (SCRIP). Circulation. 1994;89:975-90. [pmid: 8124838].
Hawe P, Higgins G. Can medication education improve the drug compliance of the elderly? Evaluation of an in hospital program Patient Educ Couns 1990 Oct 16(2):151 60 2290770
Heath GW, Ehsani AA, Hagberg JM, Hinderliter JM, Goldberg AP. Exercise training improves lipoprotein lipid profiles in patients with coronary artery disease Am Heart J 1983 Jun 105(6):889 95 6858834
Heath GW, Maloney PM, Fure CW. Group exercise versus home exercise in coronary artery bypass graft patients: effects on physical activity habits. J Cardiopulm Rehabil. 1987;7:190-5.
Hedback B, Perk J. 5-year results of a comprehensive rehabilitation programme after myocardial infarction Eur Heart J 1987 Mar 8(3):234 42 3582382
Hedback B, Perk J. Can high-risk patients after myocardial infarction participate in comprehensive cardiac rehabilitation? Scand J Rehabil Med 1990 22(1):15 20 2326603
Hedback B, Perk J, Engvall J. Predictive factors for return to work after coronary artery bypass grafting: the role of cardiac rehabilitation. Int J Rehabil Res. 1992;15:148-53. [pmid: 1526703].
Hedback BE, Perk J, Engvall J, Areskog NH. Cardiac rehabilitation after coronary artery bypass grafting: effects on exercise performance and risk factors. Arch Phys Med Rehabil. 1990 Dec;71:1069-73. [pmid: 2256808].
Hedback B, Perk J, Wodlin P. Long-term reduction of cardiac mortality after myocardial infarction: 10-year results of a comprehensive rehabilitation programme Eur Heart J 1993 Jun 14(6):831 5 8325313
Heller RF, Knapp JC, Valenti LA, Dobson AJ. Secondary prevention after acute myocardial infarction. Am J Cardiol. 1993 Oct 1;72:759-62. [pmid: 8105673].
Helmers KF, Krantz DS, Howell RH, Klein J, Bairey CN, Rozanski A. Hostility and myocardia ischemia in coronary artery disease patients: evaluation by gender and ischemic index. Psychosom Med. 1993;55:29-36. [pmid: 8446738].
Hentinen M. Need for instruction and support of the wives of patients with myocardial infarction. J Adv Nurs. 1983;8:519-24. [pmid: 6317727].
Hertzeanu HL, Shemesh J, Aron LA, Aron AL, Peleg E, Rosenthal T, Motro M, Kellermann JJ. Ventricular arrhythmias in rehabilitated and nonrehabilitated post-myocardial infarction patients with left ventricular dysfunction. Am J Cardiol. 1993;71:24-7. [pmid: 8420231].
Hoberg E, Schuler G, Kunze B, Obermoser AL, Hauer K, Mautner HP, Schlierf G, Kubler W. Silent myocardial ischemia as a potential link between lack of premonitoring symptoms and increased risk of cardiac arrest during physical stress Am J Cardiol 1990 Mar 1 65(9):583 9 2178382
Hoffmann A, Duba J, Lengyel M, Mayer K. The effect of training on the physical working capacity of MI patients with left ventricular dysfunction Eur Heart J 1987 Oct 8(Suppl G):43 9 3443125
Horwitz RI, Horwitz SM. Adherence to treatment and health outcomes. Arch Intern Med. 1993;153:1863-8. [pmid: 8250647].
Horwitz RI, Viscoli CM, Berkman L, Donaldson RM, Horwitz SM, Murray CJ, Ransohoff DF, Sindelar J. Treatment adherence and risk of death after a myocardial infarction. Lancet. 1990;336:542-5. [pmid: 1975045].
Houston Miller N, Taylor CB, Davidson DM, Hill MN, Krantz DS. The efficacy of risk factor intervention and psychosocial aspects of cardiac rehabilitation. J Cardiopulm Rehabil. 1990;10:198-209.
Hung J, Gordon EP, Houston N, Haskell WL, Goris ML, DeBusk RF. Changes in rest and exercise myocardial perfusion and left ventricular function 3 to 26 weeks after clinically uncomplicated acute myocardial infarction: effects of exercise training. Am J Cardiol. 1984;54:943-50. [pmid: 6496357].
Hung J, McKillip J, Savin W, Magder S, Kraus R, Houston N, Goris M, Haskell W, DeBusk R. Comparison of cardiovascular response to combined static-dynamic effort, postprandial dynamic effort and dynamic effort alone in patients with chronic ischemic heart disease. Circulation. 1982;65:1411-9. [pmid: 6280892].
Hypertension Detection and Follow-up Program Cooperative Group. Persistence of reduction in blood pressure and mortality of participants in the Hypertensive Hypertension Detection and Follow-up Program. JAMA. 1988;259:2113-22. [pmid: 3346988].
Ibrahim MA, Feldman JG, Sultz HA, Staiman MG, Young LJ, Dean DD. Management after myocardial infarction: a controlled trial of the effect of group psychotherapy. Int J Psychiatr Med. 1974;5:253-68.
Ignone G, Giordano A, Tavazzi L. Effects of a short-term training programme in post-infarct patients with residual myocardial ischaemia Eur Heart J 1988 Nov 9(Suppl M):13 21 3246235
Inbar G, Wallace JP, Carter S, Koester W, Rink LD. Use and risks of volleyball in cardiac rehabilitation programs. J Cardiopulm Rehabil. 1990;10:455-60.
Jensen D, Atwood JE, Froelicher V, McKirnan MD, Battler A, Ashburn W, Ross J Jr. Improvement in ventricular function during exercise studied with radionuclide ventriculography after cardiac rehabilitation Am J Cardiol 1980 Nov 46(5):770 7 7435386
Jonas MA, Oates JA, Ockene JK, Hennekens CH. Statement on smoking and cardiovascular disease for health care professionals Circulation 1992 Nov 86(5):1664 9 1423984
Jugdutt BI, Michorowski BL, Kappagoda CT. Exercise training after anterior Q wave myocardial infarction: importance of regional left ventricular function and topography. J Am Coll Cardiol. 1988;12:362-72. [pmid: 3392328].
Kallio V, Hamalainen H, Hakkila J, Luurila OJ. Reduction in sudden deaths by a multifactorial intervention programme after acute myocardial infarction Lancet 1979 2(8152): 1091 4 91836
Kane JP, Mallory MJ, Ports TA, Phillips NR, Diehl JC, Havel RJ. Regression of coronary atherosclerosis during treatment of familial hypercholesterolemia with combined drug regimens JAMA 1990 Dec 19 264(23):3007 12 2243428
Kaplan FH, Greenfield S, Ware JE Jr. Assessing the effect of physician-patient interaction on the outcome[s] of chronic disease Med Care 1989 27(3 Suppl):S110 S127 2646486
Karvetti RL, Hamalainen H. Long-term effect of nutrition education on myocardial infarction patients: a 10-year follow-up study. Nutr Metab Cardiovasc Dis. 1993 Feb 16;3:185-92.
Kavanagh T, Yacoub MH, Mertens DJ, Campbell RB, Sawyer P. Exercise rehabilitation after heterotopic cardiac transplantation. J Cardiopulm Rehabil. 1989;9:303-10.
Kavanagh T, Yacoub MH, Mertens DJ, Kennedy J, Campbell RB, Sawyer P. Cardiorespiratory responses to exercise training after orthotopic cardiac transplantation Circulation 1988 Jan 77(1):162 71 3275506
Kelemen MH. Resistance Resistive training safety and essential assessment guidelines for cardiac and coronary prone patients. Med Sci Sports Exerc. 1989;21:675-7. [pmid: 2626092].
Kellermann JJ, Ben-Ari E, Chayet M, Lapidot C, Drory Y, Fisman E. Cardiocirculatory response to different types of training in patients with angina pectoris Cardiology 1977 62(3): 218 31 890704
Kellermann JJ, Shemesh J, Fisman EZ, Steinmetz A, Ben-Ari E, Drory Y, Lapidot C. Arm exercise training in the rehabilitation of patients with impaired ventricular function and heart failure Cardiology 1990 77(2):130 8 2397489
Kennedy CC, Spiekerman RE, Lindsay MI Jr, Manken HT, Frye RL, McCallister BD. One-year graduated exercise program for men with angina pectoris: evaluation by physiologic studies and coronary arteriography Mayo Clin Proc 1976 Apr 51(4):231 6 1263594
Kentala E. Physical fitness and feasibility of physical rehabilitation after myocardial infarction in men of working age Ann Clin Res 1972 4(Suppl 9):1 84 4655644
Keteyian S, Ehrman J, Fedel F, Rhoads K. Heart rate-perceived exertion relationship during exercise in orthotopic heart transplant patients. J Cardiopulm Rehabil. 1990;10:287-93.
Kimball CP. Psychological responses to the experience of open heart surgery: I. Am J Psychiatry. 1969;126:348-59. [pmid: 5801253].
King AC, Haskell WL, Taylor CB, Kraemer HC, DeBusk RF. Group- vs home-based exercise training in healthy older men and women: a community-based clinical trial JAMA 1991 Sept 18 266(11):1535 42 1880885
Kinney MR, Packa DR. Measuring the unmeasurable: quality of life. Cardiovasc Nurs. 1988;24:52-3. [pmid: 3203364].
Kinsey GM, Fletcher BJ, Rice CR, Watson PH, Fletcher GF. Coronary risk factor modification followed by home-monitored exercise in coronary bypass surgery patients: a four-year follow-up study. J Cardiopulm Rehabil. 1989;9:207-12.
Konstam M, Dracup K, Baker D, Bottorff MB, Brooks, NH, Dacey RA, Dunbar SB, Jackson AB, Jessup M, et al. Heart failure: evaluation and care of patients with left-ventricular systolic dysfunction Clinical practice guideline no. 11 AHCPR publication no. 94-0612, Rockville, MD: Agency for Health Care Policy and Research, Public Health Service, U.S. Department of Health and Human Services. June 1994
Kop WJ, Appels AP, Mendes de Leon CF, de Swart HB, Bar FW. Vital exhaustion predicts new cardiac events after successful coronary angioplasty Psychosom Med 1994 July-Aug 56(4):281 7 7972608
Kravitz RL, Hays RD, Sherbourne CD, DiMatteo MR, Rogers WH, Ordway L, Greenfield S. Recall of recommendations and adherence to advice among patients with chronic medical conditions. Arch Intern Med. 1993;153:1869-78. [pmid: 8250648].
Lamm G, Denolin H, Dorossiev D, Pisa Z. Rehabilitation and secondary prevention of patients after acute myocardial infarction. Adv Cardiol. 1982;31:107-11. [pmid: 6758500].
Langer RD, Klauber MR, Criqui MH, Barrett-Connor EL. Exercise and survival in the very old. Am J Geriatr Cardiol. 1994 July-Aug:24-34. [pmid: 11416312].
Langosch W, Seer P, Brodner G, Kallinke D, Kullick B, Heim F. Behavior therapy with coronary heart disease patients: results of a comparative study J Psychosom Res 1982 26(5):475 84 6759642
Lavie CJ, Milani RV, Littman AB. Benefits of cardiac rehabilitation and exercise training in secondary coronary prevention in the elderly. J Am Coll Cardiol. 1993 Sept;22:678-83. [pmid: 8354798].
Lee AP, Ice R, Blessey R, Sanmarco ME. Long-term effects of physical training on coronary patients with impaired ventricular function Circulation 1979 Dec 60(7):1519 26 115617
Leon AS, Certo C, Comoss P, Franklin BA, Froelicher V, Haskell WL, Hellerstein HK, Marley WP, Pollock ML, Ries A, et al. Scientific evidence of the value of cardiac rehabilitation services with emphasis on patients following myocardial infarction—section I: exercise conditioning component [position paper]. J Cardiopulm Rehabil. 1990;10:79-87.
Letac B, Cribier A, Desplanches JF. A study of left ventricular function in coronary patients before and after physical training Circulation 1977 Sept 56(3):375 8 884793
Levin LA, Perk J, Hedback B. Cardiac rehabilitation—a cost analysis. J Intern Med. 1991;230:427-34. [pmid: 1940778].
Lindskog BD, Sivarajan ES. A method of evaluation of activity and exercise in a controlled study of early cardiac rehabilitation. J Cardiac Rehabil. 1982;2:156-65.
Maresh CM, Harbecht JJ, Flick BL, Hartzler GO. Comparison of rehabilitation benefits after percutaneous transluminal coronary angioplasty and coronary artery bypass graft surgery. J Cardiopulm Rehabil. 1985;5:124-30.
Mark DB, Naylor CD, Hlatky MA, Califf RM, Topol EJ, Granger CB, Knight JD, Nelson CL, Lee KL, Clapp- Channing NE, et al. Use of medical resources and quality of life after acute myocardial infarction in Canada and the United States. N Engl J Med. 1994;331:1130-5. [pmid: 7935638].
Marra S, Paolillo V, Spadaccini F, Angeleno PF. Long-term follow-up after a controlled randomized post-myocardial infarction rehabilitation programme: effects on morbidity and mortality. Eur Heart J. 1985;6:656-63. [pmid: 4054135].
Matthews KA, Glass DC, Rosenman RH, Bortner RW. Competitive drive, pattern A, and coronary heart disease: a further analysis of some data from the Western Collaborative Group Study J Chronic Dis 1977 Aug 30(8):489 98 893653
May GA, Nagle FJ. Changes in rate-pressure product with physical training of individuals with coronary artery disease Phys Ther 1984 Sept 64(9):1361 6 6473517
Mayou R, MacMahon D, Sleight P, Florencio MJ. Early rehabilitation after myocardial infarction Lancet 1981 2(8260-61):1399 4 02 6118768
McCartney N, McKelvie RS, Haslam DR, Jones NL. Usefulness of weightlifting training in improving strength and maximal power output in coronary artery disease. Am J Cardiol. 1991 May;67:939-45. [pmid: 2018011].
Meyer TR, Casadei B, Coats AJ, Davey PP, Adamopoulos S, Radaelli A, Conway J. Angiotensin-converting enzyme inhibition and physical training in heart failure. J Intern Med. 1991;230:407-13. [pmid: 1658183].
Milani RV, Littman AB, Lavie CJ. Depressive symptoms predict functional improvement following cardiac rehabilitation and exercise program. J Cardiopulm Rehabil. 1993;13:406-11.
Miller A. When is the time for teaching?. Am J Nurs. 1985;85:801-4. [pmid: 3848277].
Miller NH, Haskell WL, Berra K, DeBusk RF. Home versus group exercise training for increasing functional capacity after myocardial infarction. Circulation. 1984;70:645-9. [pmid: 6478567].
Monpere C, Francois G, Brochier M. Effects of a comprehensive rehabilitation programme in patients with three-vessel coronary disease Eur Heart J 1988 Nov 9(Suppl M):28 31 3246238
Morris LS, Schulz RM. Patient compliance—an overview. J Clin Pharm Ther. 1992;17:283-95. [pmid: 1464632].
Mulcahy R. Influence of cigarette smoking on morbidity and mortality after myocardial infarction. Br Heart J. 1983;49:410-5. [pmid: 6340707]. [pmcid: 481325].
Mullen PD, Mains DA, Velez R. A meta-analysis of controlled trials of cardiac patient education. Patient Educ Couns. 1992;19:143-62. [pmid: 1299819].
Munro BH, Creamer AM, Haggerty MR, Cooper FS. Effect of relaxation therapy on post-myocardial infarction patients' rehabilitation Nurs Res 1988 July-Aug 37(4):231 5 3293026
Murray PM, Herrington DM, Pettus CW, Miller HS, Cantwell JD, Little WC. Should patients with heart disease exercise in morning or afternoon?. Arch Intern Med. 1993 Apr 12;153:833-6. [pmid: 8466375].
Myrtek M. Life satisfaction, illness behaviour, and rehabilitation outcome: results of a one year follow-up study with cardiac patients Int J Rehabil Res 1987 10(4):373 82 3503824
National Cholesterol Education Program. The second report of the Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel II) NIH publication no. 93-3095, Bethesda (MD):National Institutes of Health, National Heart, Lung, and Blood Institute;Sep. 1993
National High Blood Pressure Education Program. The fifth report of the Joint National Committee on Detection, Evaluation and Treatment of High Blood Pressure NIH publication no. 93-1088, Bethesda (MD):National Institutes of Health, National Heart, Lung, and Blood Institute;Jan. 1993
Nau KL, Katch VL, Tsai AC. Omega-3 polyunsaturated fatty acid supplementation alters selective plasma lipid values in adults with heart disease. J Cardiopulm Rehabil. 1991;11:386-91.
Naughton J, Bruhn JG, Lategola MG. Effects of physical training on physiologic and behavioral characteristics of cardiac patients Arch Phys Med Rehabil 1968 Mar 49(3):131 7 4384805
Newton KM, Sivarajan ES, Bruce RA, Mansfield L. Cost of hospitalization and loss of income following myocardial infarction [abstract] Circulation 1981 64(Suppl IV):
Newton KM, Sivarajan ES, Clarke JL. Patient perceptions of risk factor changes and cardiac rehabilitation outcomes after myocardial infarction. J Cardiopulm Rehabil. 1985;5:159-68.
Newton M, Mutrie N, McCarthur JD. McArthur JD. The effects of exercise in a coronary rehabilitation programme Scott Med J 1991 Apr 36(2):38 41 1853191
Nikolaus T, Schlierf G, Vogel G, Schuler G, Wagner I. Treatment of coronary heart disease with diet and exercise—problems of compliance Ann Nutr Metab 1991 35(1):1 7 2058997
Niset G, Coustry-Degre C, Degre S. Psychosocial and physical rehabilitation after heart transplantation: 1-year follow-up Cardiology 1988 75(4):311 7 3048669
Nolewajka AJ, Kostuk WJ, Rechnitzer PA, Cunningham DA. Exercise and human collateralization: an angiographic and scintigraphic assessment Circulation 1979 Jul 60(1):114 21 445714
Oberman A, Cleary P, Larosa JC, Hellerstein HK, Naughton J. Changes in risk factors among participants in a long-term exercise rehabilitation program. Adv Cardiol. 1982;31:168-75. [pmid: 6817597].
O'Connor GT, Buring JE, Yusuf S, Goldhaber SZ, Olmstead EM, Paffenbarger RS Jr, Hennekens CH. An overview of randomized trials of rehabilitation with exercise after myocardial infarction Circulation 1989 Aug 80(2):234 44 2665973
Oldridge NB. Compliance with cardiac rehabilitation services. J Cardiopulm Rehabil. 1991;11:115-27.
Oldridge N, Furlong W, Feeny D, Torrance G, Guyatt G, Crowe J, Jones N. Economic evaluation of cardiac rehabilitation soon after acute myocardial infarction. Am J Cardiol. 1993;72:154-61. [pmid: 8328376].
Oldridge NB, Guyatt GH, Fischer ME, Rimm AA. Cardiac rehabilitation after myocardial infarction: combined experience of randomized clinical trials JAMA 1988 Aug 19 260(7):945 50 3398199
Oldridge NB, Guyatt G, Jones N, Crowe J, Singer J, Feeny D, McKelvie R, Runions J, Streiner D, Torrance G. Effects on quality of life with comprehensive rehabilitation after acute myocardial infarction. Am J Cardiol. 1991;67:1084-9. [pmid: 2024598].
Oldridge NB, Haskell WL, Single P. Carotid palpation, coronary heart disease and exercise rehabilitation Med Sci Sports Exerc 1981 13(1):6 8 7219136
Oldridge NB, Jones NL. Improving patient compliance in cardiac exercise rehabilitation: effects of written agreement and self-monitoring. J Cardiopulm Rehabil. 1983;3:257-62.
Oldridge NB, McCartney N, Hicks A, Jones NL. Improvement in maximal isokinetic cycle ergometry with cardiac rehabilitation Med Sci Sports Exerc 1989 Jun 21(3):308 12 2733581
Ornish D, Brown SE, Scherwitz LW, Billings Armstrong WT, Ports TA, McLanahan SM, Kirkeeide RL, Braud RJ, Gould KL. Can lifestyle changes reverse coronary heart disease? The Lifestyle Heart Trial. Lancet. 1990;336:129-33. [pmid: 1973470].
Ornish D, Scherwitz LW, Doody RS, Kesten D, McLanahan SM, Brown SE, DePuey EG, Sonnemaker R, Haynes C, Lester J, McAllister GK, Hall RJ, Burdine JA, Gotto AM Jr. Effects of stress management training and dietary changes in treating ischemic heart disease JAMA 1983 Jan 7 249(1):54 9 6336794
Ott CR, Sivarajan ES, Newton KM, Almes MJ, Bruce RA, Bergner M, Gilson BS. A controlled randomized study of early cardiac rehabilitation: the Sickness Impact Profile as an assessment tool. Heart Lung. 1983;12:162-70. [pmid: 6550047].
Palatsi I. Feasibility of physical training after myocardial infarction and its effect on return to work, morbidity and mortality Acta Med Scand 1976 Aug 23(Suppl 599):7 84
Parmley, WW. Position report on cardiac rehabilitation: recommendations of the American College of Cardiology on cardiovascular rehabilitation. J Am Coll Cardiol. 1986;7:451-3. [pmid: 3711468].
Pashkow FJ, Dafoe WA, editors. Clinical cardiac rehabilitation: a cardiologist's guide, Baltimore:Williams & Wilkins;1993
Pate RR, Pratt M, Blair SN, Haskell WL, Macera CA, Bouchard C, Buchner D, Ettinger W, Heath GW, King AC, et al. Physical activity and public health: a recommendation from the Centers for Disease Control and Prevention and the American College of Sports Medicine JAMA 1995 Feb 1 273(5):402 7 7823386
Perk J, Hedback B, Jutterdal S. Cardiac rehabilitation: evaluation of long-term programme of physical training for out-patients. Scand J Rehabil Med. 1989;21:13-7. [pmid: 2496462].
Pfeffer MA, Braunwald E, Moye LA, Basta L, Brown EJ Jr, Cuddy TE, Davis BR, Geltman EM, Goldman S, Flaker GC, et al. Effect of captopril on mortality and morbidity in patients with left ventricular dysfunction after myocardial infarction: results of the survival and ventricular enlargement trial N Engl J Med 1992 Sept 3 327(10):669 77 1386652
Picard MH, Dennis C, Schwartz RG, Ahn DK, Kraemer HC, Berger WE 3d, Blumberg R, Heller R, Lew H, DeBusk RF. Cost-benefit analysis of early return to work after uncomplicated acute myocardial infarction. Am J Cardiol. 1989;63:1308-14. [pmid: 2499172].
Pilote L, Thomas RJ, Dennis C, Goins P, Houston-Miller N, Kraemer H, Leong C, Berger WE 3d, Lew H, Heller RS, et al. Return to work after uncomplicated myocardial infarction: a trial of practice guidelines in the community. Ann Intern Med. 1992;117:383-9. [pmid: 1503329].
Plavsic C, Turkulin K, Perman Z, Steinel S, Oreskovic A, Dimnik R, Martic P, Fischer F, Puharic M, Bruketa I, Martic M, Stojanovic D, Ljubetic L. The results of exercise therapy in coronary prone individuals and coronary patients G Ital Cardiol 1976 6(3):422 32 1010193
Pratt CM, Welton DE, Squires WG Jr, Kirby TE, Hartung GH, Miller RR. Demonstration of training effect during chronic beta-adrenergic blockade in patients with coronary artery disease Circulation 1981 Dec 64(6):1125 9 6117378
P.R.E. Cor Group. Comparison of a rehabilitation programme, a counselling programme and usual care after an acute myocardial infarction: results of a long-term randomized trial. Eur Heart J. 1991;12:612-6. [pmid: 1874262].
Psaty BM, Koepsell TD, Wagner EH, LoGerfo JP, Inui TS. The relative risk of incident coronary heart disease associated with recently stopping the use of beta-blockers. JAMA. 1990;263:1653-7. [pmid: 1968518].
Raft D, McKee DC, Popio KA, Haggerty JJ Jr. Life adaptation after percutaneous transluminal coronary angioplasty and coronary artery bypass grafting Am J Cardiol 1985 Sept 56(7):395 8 2931012
Rahe RH, Ward HW, Hayes V. Brief group therapy in myocardial infarction rehabilitation: three- to four-year follow-up of a controlled trial Psychosom Med 1979 May 41(3):229 42 314119
Raineri A, Assennato P, Candela B, Messina L. Short- and long-term results of early rehabilitation after myocardial infarction: physical fitness, hemodynamic assessments and psychological aspects Cardiology 1982 69(4):231 41 6816468
Razin AM, Swencionis C, Zohman LR. Reduction of physiological, behavioral, and self-report responses in type A behavior: a preliminary report Int J Psychiatry Med 1986-87 16(1):32 47
Rechnitzer PA, Cunningham DA, Andrew GM, Buck CW, Jones NL, Kavanagh T, Oldridge NB, Parker JO, Shephard RJ, Sutton JR, et al. Ontario Exercise-Heart Collaborative Study: relation of exercise to the recurrence rate of myocardial infarction in men. Am J Cardiol. 1983;51:65-9. [pmid: 6336877].
Rechnitzer PA, Pickard HA, Paivio AU, Yuhasz MS, Cunningham D. Long-term follow-up study of survival and recurrence rates following myocardial infarction in exercising and control subjects. Circulation. 1972 Apr;45:853-7. [pmid: 5016018].
Redwood DR, Rosing DR, Epstein SE. Circulatory and symptomatic effects of physical training in patients with coronary-artery disease and angina pectoris N Engl J Med 1972 May 4 286(18):959 65 5015440
Review Panel on Coronary-Prone Behavior and Coronary Heart Disease. Coronary-prone behavior and coronary heart disease: a critical review Circulation 1981 Jun 63(6):1199 215 7014026
Ribiero JP, Hartley LH, Sherwood J, Herd JA. The effectiveness of a low lipid diet and exercise in the management of coronary artery disease Am Heart J 1984 Nov 108(5):1183 9 6496276
RITA Trial Participants. Coronary angioplasty versus coronary artery bypass surgery: the Randomized Intervention Treatment of Angina (RITA) trial. Lancet. 1993;341:573-80. [pmid: 8094826].
Roman O, Gutierrez M, Luksic I, Chavez E, Camuzzi AL, Villalon E, Klenner C, Cumsille F. Cardiac rehabilitation after acute myocardial infarction: 9-year controlled follow-up study Cardiology 1983 70(4):223 31 6640562
Rosenman RH, Brand RJ, Jenkins D, Friedman M, Strauss R, Wurm M. Coronary heart disease in Western Collaborative Group Study: final follow-up experience of 8-1/2 years. JAMA. 1975;233:872-7. [pmid: 1173896].
Roter DL. Patient participation in patient-provider interaction: the effects of patient questions asking on the quality of interaction, satisfaction and compliance. Health Educ Monogr. 1977;5:281-315. [pmid: 346537].
Roviaro S, Holmes DS, Holmsten RD. Influence of a cardiac rehabilitation program on the cardiovascular, psychological, and social functioning of cardiac patients. J Behav Med. 1984;7:61-81. [pmid: 6609243].
Sallis JF, Flora JA, Fortmann SP, Taylor CB, Maccoby N. Mediated smoking cessation programs in the Stanford Five-City Project. Addict Behav. 1985;10:441-3. [pmid: 4091078].
Scalzi CC, Burke LE, Greenland S. Evaluation of an inpatient educational program for coronary patients and families. Heart Lung. 1980;9:846-53. [pmid: 6904414].
Scandinavian Simvastatin Survival Study Group. Randomised trial of cholesterol lowering in 4444 patients with coronary heart disease: the Scandinavian Simvastatin Survival Study (4S). Lancet. 1994 Nov 19;344:1838-9.
Schiller E, Baker J. Return to work after a myocardial infarction: evaluation of planned rehabilitation and of a predictive rating scale. Med J Aust. 1976 Jun;1:859-62. [pmid: 967080].
Schleifer SJ, Macari-Hinson MM, Coyle DA, Slater WR, Kahn M, Gorlin R, Zucker HD. The nature and course of depression following myocardial infarction. Arch Intern Med. 1989;149:1785-9. [pmid: 2788396].
Schram V, Hanson P. Cardiovascular and metabolic responses to weight-loaded walking in cardiac rehabilitation patients. J Cardiopulm Rehabil. 1988;8:28-32.
Schuler G, Hambrecht R, Schlierf G, Grunze M, Methfessel S, Hauer K, Kubler W. Myocardial perfusion and regression of coronary artery disease in patients on a regimen of intensive physical exercise and low fat diet. J Am Coll Cardiol. 1992a;19:34-42. [pmid: 1729343].
Schuler G, Hambrecht R, Schlierf G, Niebauer J, Hauer K, Neumann J, Hoberg E, Drinkmann A, Bacher F, Grunze M. Regular physical exercise and low-fat diet: effects of progression of coronary artery disease. Circulation. 1992b;86:1-11. [pmid: 1617762].
Sebrechts CP, Klein JL, Ahnve S, Froelicher VF, Ashburn WL. Myocardial perfusion changes following 1 year of exercise training assessed by thallium-201 circumferential count profiles Am Heart J 1986 Dec 112(6):1217 26 3491531
Sennett SM, Pollock ML, Pels AE 3d, Foster C, Dolatowski R, Laughlin J, Patel S, Schmidt DH. Medical problems of patients in an outpatient cardiac rehabilitation program. J Cardiopulm Rehabil. 1987;7:458-65.
Shaw LW. Effects of a prescribed supervised exercise program on mortality and cardiovascular morbidity in patients after myocardial infarction: The National Exercise and Heart Disease Project Am J Cardiol 1981 Jul 48(1):39 46 6972693
Shekelle RB, Gale M, Norusis M. Type A score (Jenkins Activity Survey) and risk of recurrent coronary heart disease in the aspirin myocardial infarction study. Am J Cardiol. 1985;56:221-5. [pmid: 3895879].
Shekelle RB, Gale M, Ostfeld AM, Paul O. Hostility, risk of coronary heart disease, and mortality. Psychosom Med. 1983;45:109-14. [pmid: 6867229].
Shekelle RB, Hulley SB, Neaton JD, Billing JH, Borhani NO, Gerace TA, Jacobs DR, Lasser NL, Mittlemark MB, Stamler J. The MRFIT behavior pattern study: II. type A behavior pattern and risk of coronary heart disease. Am J Epidemiol. 1985;122:559-70. [pmid: 4025299].
Sheldahl LM, Wilke NA, Tristani FE, Kalbfleisch JH. Response of patients after myocardial infarction to carrying a graded series of weight loads Am J Cardiol 1983 Oct 1 52(7):698 703 6624661
Shephard RJ, Corey P, Kavanagh T. Exercise compliance and the prevention of a recurrence of myocardial infarction Med Sci Sports Exerc 1981 13(1):1 5 7219128
Shumaker SA, Schron EB, Ockene JK, senior editors; Parker CT, Probstfield JL, Wolle JM, co-editors. The handbook of health behavior change, New York:Springer; 1990.
Sikorski JM. Knowledge, concerns and questions of wives of convalescent coronary artery bypass graft surgery patients. J Cardiopulm Rehabil. 1985;5:74-85.
Simpson M, Buckman R, Stewart M, Maguire P, Lipkin M, Novack D, Till J. Doctor-patient communication: the Toronto consent statement. Br Med J. 1991;303:1385-7. [pmid: 1760608]. [pmcid: 1671610].
Singh RB, Rastogi SS, Verma R, Laxmi B, Singh R, Ghosh S, Niaz MA. Randomised controlled trial of cardioprotective diet in patients with recent acute myocardial infarction: results of one year follow up. Br Med J. 1992;304:1015-9. [pmid: 1586782]. [pmcid: 1881705].
Sivarajan ES, Bruce RA, Almes MJ, Green B, Belanger L, Lindskog BD, Newton KM, Mansfield LW. In-hospital exercise after myocardial infarction does not improve treadmill performance N Engl J Med 1981 307(7):357 362 7019706
Sivarajan ES, Bruce RA, Lindskog BD, Almes MJ, Belanger L, Green B. Treadmill test responses to an early exercise program after myocardial infarction: a randomized study Circulation 1982 Jun 65(7):1420 8 7074797
Sivarajan ES, Newton KM. Exercise, education, and counseling for patients with coronary artery disease Clin Sports Med 1984 3(2):349 69 6388856
Sivarajan ES, Newton KM, Almes MJ, Kempf TM, Mansfield LW, Bruce RA. Limited effects of outpatient teaching and counseling after myocardial infarction: a controlled study Heart Lung 1983 Jan 12(1):65 73 6549638
Sivarajan ES, Snydsman A, Smith B, Irving JB, Mansfield LW, Bruce RA. Low-level treadmill testing of 41 patients with acute myocardial infarction prior to discharge from hospital Heart Lung 1977 Dec 6(6):975 80 244326
Sivarajan Froelicher ES. Understanding and reducing measurement error. Cardiovasc Nurs. 1988;24:48-49. [pmid: 3203360].
Sivarajan Froelicher E, Perdue ST. Clinical, epidemiological, and statistical methods used in prognostic studies of survival after myocardial infarction. J Cardiopulm Rehabil. 1991;11:16-22.
Smith LK, Layton K, Newmark JL, Diethrich EB. An intensive cardiovascular rehabilitation program for patients with disabling angina and diffuse coronary artery disease. J Cardiopulm Rehabil. 1987;7:425-9.
SOLVD Investigators. Effect of enalapril on survival in patients with reduced left ventricular ejection fractions and congestive heart failure. N Engl J Med. 1991;325:293-302. [pmid: 2057034].
SOLVD Investigators. Effect of enalapril on mortality and the development of heart failure in asymptomatic patients with reduced left ventricular ejection fractions. N Engl J Med. 1992;327:685-91. [pmid: 1463530].
Sotile WM, Sotile MO, Ewen GS, Sotile LJ. Marriage and family factors relevant to effective cardiac rehabilitation: a review of risk factor literature. Sports Med Training Rehabil. 1993;4:115-28.
Sparling PB, Cantwell JD, Dolan CM, Niederman RK. Strength training in a cardiac rehabilitation program: a six-month follow-up Arch Phys Med Rehabil 1990 Feb 71(2):148 52 2302049
Stern MJ, Cleary P. National Exercise and Heart Disease Project: psychosocial changes observed during a low-level exercise program. Arch Intern Med. 1981 Oct;141:1463-7. [pmid: 7283557].
Stern MJ, Gorman PA, Kaslow P. The group counseling v exercise therapy [study]: a controlled intervention with subjects following myocardial infarction. Arch Intern Med. 1983;143:1719-25. [pmid: 6615094].
Stern MJ, Pascale L, Ackerman A. Life adjustment postmyocardial infarction: determining predictive variables. Arch Intern Med. 1977;137:1680-5. [pmid: 931475].
Stevens R, Hanson P. Comparison of supervised and unsupervised exercise training after coronary bypass surgery. Am J Cardiol. 1984 Jun;53:1524-8. [pmid: 6145353].
Stevenson LW, Steimle AE, Fonarow G, Kermani M, Kermani D, Hamilton MA, Moriguchi JD, Walden J, Tillisch JH, Drinkwater DC, et al. Improvement in exercise capacity of candidates awaiting heart transplantation J Am Coll Cardiol 1995 Jan 25(1):163 70 7798496
Stewart KJ, Mason M, Kelemen MH. Three-year participation in circuit weight training improves muscular strength and self-efficacy in cardiac patients. J Cardiopulm Rehabil. 1988;8:292-6.
Streja D, Mymin D. Moderate exercise and high-density lipoprotein-cholesterol: observations during a cardiac rehabilitation program JAMA 1979 Nov 16 242(20):2190 2 226733
Stuart RJ, Koyal SN, Lundstrom R, Thomas L, Ellestad MH. Does exercise training alter maximal oxygen uptake in coronary artery disease during long-term beta-adrenergic blockade?. J Cardiopulm Rehabil. 1985;5:410-14.
Sullivan MJ, Higginbotham NB, Cobb FR. Exercise training in patients with severe left ventricular dysfunction: hemodynamic and metabolic effects Circulation 1988 Sep 78(3):506 15 3409495
Sullivan MJ, Higginbotham MB, Cobb FR. Exercise training in patients with chronic heart failure delays ventilatory anaerobic threshold and improves submaximal exercise performance. Circulation. 1989;79:324-9. [pmid: 2914350].
Superko HR. Effects of cardiac rehabilitation in permanently paced patients with third-degree heart block. J Cardiopulm Rehabil. 1983;3:561-8.
Taylor CB, Bandura A, Ewart CK, Miller NH, DeBusk RF. Exercise testing to enhance wives' confidence in their husbands' cardiac capability soon after clinically uncomplicated acute myocardial infarction Am J Cardiol 1985 Mar 1 55(6):635 8 3976503
Taylor CB, Houston-Miller N, Ahn DK, Haskell W, DeBusk RF. The effects of exercise training programs on psychosocial improvement in uncomplicated postmyocardial infarction patients. J Psychosom Res. 1986;30:581-7. [pmid: 3772840].
Taylor CB, Houston-Miller N, Haskell WL, DeBusk RF. Smoking cessation after acute myocardial infarction: the effects of exercise training. Addict Behav. 1988;13:331-5. [pmid: 3239464].
Taylor CB, Houston-Miller N, Killen JD, DeBusk RF. Smoking cessation after acute myocardial infarction: effects of a nurse-managed intervention Ann Intern Med 1990 Jul 15 113(2):118 23 2360750
Thoresen CE, Friedman M, Powell LH, Gill JJ, Ulmer D. Altering the type A behavior pattern in postinfarction patients. J Cardiopulm Rehabil. 1985;5:258-66.
Todd IC, Ballatyne D. Effect of exercise training on the total ischaemic burden: an assessment by 24 hour ambulatory electrocardiographic monitoring Br Heart J 1992 Dec 68(6):560 6 1467049 1025685
Tubau J, Witztum K, Froelicher V, Jensen D, Atwood E, McKirnan MD, Reynolds J, Ashburn W. Noninvasive assessment of changes in myocardial perfusion and ventricular performance following exercise training Am Heart J 1982 Aug 104(2 Pt 1):238 48 7102507
U.S. Preventive Services Task Force. Guide to clinic preventive services, Baltimore:Williams & Wilkins;1989
Van Camp SP, Peterson RA. Cardiovascular complications of outpatient cardiac rehabilitation programs. JAMA. 1986;256:1160-3. [pmid: 3735650].
Van Camp SP, Peterson RA. Identification of the high risk cardiac rehabilitation patient. J Cardiopulm Rehabil. 1989;9:103-9.
van Dixhoorn J, Duivenvoorden J, Staal JA, Pool J, Verhage F. Cardiac events after myocardial infarction: possible effect of relaxation therapy. Eur Heart J. 1987;8:1210-4. [pmid: 3319629].
Vanhees L, Fagard R, Amery A. Influence of beta-adrenergic blockade on the hemodynamic effects of physical training in patients with ischemic heart disease Am Heart J 1984 108(2): 270 5 6147076
Verani MS, Hartung GH, Hoepfel-Harris J, Welton DE, Pratt CM, Miller PR. Effects of exercise training on left ventricular performance and myocardial perfusion in patients with coronary artery disease Am J Cardiol 1981 Apr 47(4):797 803 7211694
Vermeulen A, Lie K, Durrer D. Effects of cardiac rehabilitation after myocardial infarction: changes in coronary risk factors and long-term prognosis. Am Heart J. 1983;105:789-801. [pmid: 6846123].
Waites TF, Watt EW, Fletcher GF. Comparative functional and physiologic status of active and dropout coronary bypass patients of a rehabilitation program Am J Cardiol 1983 Apr 51(7):1087 90 6601451
Walling A, Tremblay GJ, Jobin J, Charest J, Delage F, Leblanc MH, Tessier Y, Villa I. Evaluating the rehabilitation potential of a large population of post-myocardial infarction patients: adverse prognosis for women. J Cardiopulm Rehabil. 1988;8:99-106.
Walter PJ, editor. Return to after coronary artery bypass surgery: psychosocial and economic aspectsBerlin:Springer-Verlag;1985
Watts GF, Lewis B, Brunt JN, Lewis ES, Coltart DJ, Smith LD, Mann JI, Swan AV. Effects on coronary artery disease of lipid-lowering diet, or diet plus cholestyramine, in the St Thomas' Atherosclerosis Regression Study (STARS) Lancet 1992 Mar 7 339(8793):563 9 1347091
Wenger NK. Impairment, disability, and the cardiac patient (editorial). Qual Life Cardiovasc Care. 1987 Summer;3.
Wenger NK. Rehabilitation after cardiovascular diseases: report and recommendations of a World Health Organization Expert Committee (October 1991). Int J Sports Cardiol. 1992;1:101-3.
Wenger NK, Balady GJ, Cohen LH, Hartley LH, King SB III, Miller HS Jr, Weiner DA (the Ad Hoc Task Force on Cardiac Rehabilitation). Cardiac rehabilitation services following PTCA and valvular surgery: guidelines for use. Cardiology. 1990;19:4-5.
Wenger NK, Haskell WL, Kanter K, Squires RW, Yusuf S (the Ad Hoc Task Force on Cardiac Rehabilitation). Cardiac rehabilitation services after cardiac transplantation: guidelines for use. Cardiology. 1991;20:4-5.
Wenger NK, Hellerstein HK, editors. Rehabilitation of the coronary patient 3rd ed, New York:Churchill Livingstone; 1992.
Wenger NK, Hellerstein HK, Blackburn H, Castranova SJ. Physician practice in the management of patients with uncomplicated myocardial infarction: changes in the past decade Circulation 1982 Mar 65(3):421 7 6276043
Wilhelmsen L, Sanne H, Elmfeldt D, Grimby G, Tibblin G, Wedel H. A controlled trial of physical training after myocardial infarction: effects on risk factors, nonfatal reinfarction, and death. Prev Med. 1975;4:491-508. [pmid: 1208362].
Wilke NA, Sheldahl LM, Levandoski SG, Hoffman MD, Dougherty SM, Tristani FE. Transfer effect of upper extremity training to weight carrying in men with ischemic heart disease. J Cardiopulm Rehabil. 1991;11:365-72.
Williams MA, Maresh CM, Esterbrooks DJ, Harbrecht JJ, Sketch MH. Early exercise training in patients older than age 65 years compared with that in younger patients after acute myocardial infarction or coronary artery bypass grafting. Am J Cardiol. 1985;55:263-6. [pmid: 2857521].
Williams RB Jr, Barefoot JC, Haney TL, Harrell FE Jr, Blumenthal JA, Pryor DB, Peterson B. Type A behavior and angiographically documented coronary atherosclerosis in a sample of 2,289 patients Psychosom Med 1988 Mar-Apr 50(2):139 52 3375404
Wood PD, Stefanick ML, Williams PT, Haskell WL. The effects on plasma lipoprotein of a prudent weight-reducing diet, with or without exercise, in overweight men and women. N Engl J Med. 1991;325:461-6. [pmid: 1852180].
Woods SL, Sivarajan Froelicher ES, Halpenny CJ, Underhill Motseir S, editors. Cardiac nursing 3rd ed, Philadelphia:Lippincott;1994
Worcester MC, Hare DL, Oliver RG, Reid MA, Goble AJ. Early programmes of high and low intensity exercise and quality of life after acute myocardial infarction. Br Med J. 1993 Nov 13;307:1244-7. [pmid: 8281056].
World Health Organization Expert Committee. Rehabilitation after cardiovascular diseases, with special emphasis on developing countries Technical report series no. 831, Geneva: World Health Organization; 1993
Wrisley D, Rubenfire M. Ineffectiveness of standardized dietary counseling in hypercholesterolemic patients with coronary disease. J Cardiopulm Rehabil. 1988;8:226-30.
Yalom ID. The theory and practice of group psychotherapy 2nd ed, NewYork:Basic Books; 1975. 1124974
Yates BC, Booton-Hiser DA. Comparison of psychologic stress responses in patients and spouses ten weeks after a cardiac illness event Prog Cardiovasc Nurs 1992 Oct-Dec 7(4):25 33 1301568
Zohman LR, Tobis JS. The effect of exercise training on patients with angina pectoris Phys Med Rehabil 1967 Oct 48(10):525 32