# Executive Summary

## Introduction

Cardiovascular disease is the leading cause of morbidity and mortality in the United States, accounting for over 50 percent of all deaths. Coronary heart disease (CHD), with its clinical manifestations of stable angina pectoris, unstable angina, acute myocardial infarction, and sudden cardiac death, affects 13.5 million Americans. The almost 1 million survivors of myocardial infarction and the 7 million patients with stable angina pectoris are candidates for cardiac rehabilitation, as are the 309,000 patients who undergo coronary artery bypass graft (CABG) surgery and the 362,000 patients who undergo percutaneous transluminal coronary angioplasty (PTCA) and other transcatheter procedures each year. An estimated 4.7 million patients with heart failure may also be eligible. Although beneficial outcomes from cardiac rehabilitation services can be expected in most of these patients, few such patients currently participate in cardiac rehabilitation programs.

The U.S. Public Health Service definition of cardiac rehabilitation, used by the panel, states that "cardiac rehabilitation services are comprehensive, long-term programs involving medical evaluation, prescribed exercise, cardiac risk factor modification, education, and counseling. These programs are designed to limit the physiologic and psychological effects of cardiac illness, reduce the risk for sudden death or reinfarction, control cardiac symptoms, stabilize or reverse the atherosclerotic process, and enhance the psychosocial and vocational status of selected patients." This guideline provides recommendations for cardiac rehabilitation services for patients with CHD and with heart failure, including those awaiting or following cardiac transplantation.

This guideline is designed for use by health practitioners who provide care to patients with cardiovascular disease. These include physicians (primary care, cardiologists, and cardiovascular surgeons), nurses, exercise physiologists, dietitians, behavioral medicine specialists, psychologists, and physical and occupational therapists. The information can guide clinical decisionmaking regarding referral and followup of patients for cardiac rehabilitation services as well as administrative decisions regarding the availability of and access to cardiac rehabilitation services.

This guideline details the outcomes that result from cardiac rehabilitation services. The interventions examined involve two parallel applications: (1) exercise training and (2) education, counseling, and behavioral interventions. The panel emphasizes the added effectiveness of multifactorial cardiac rehabilitation services integrated in a comprehensive approach.

## Outcomes of Cardiac Rehabilitation Services

The results of cardiac rehabilitation services, based on reports in the scientific literature, are summarized in this guideline. The most substantial benefits include:

- Improvement in exercise tolerance.
- Improvement in symptoms.
- Improvement in blood lipid levels.
- Reduction in cigarette smoking.
- Improvement in psychosocial well-being and reduction of stress.
- Reduction in mortality.

### Improvement in Exercise Tolerance

Cardiac rehabilitation exercise training improves objective measures of exercise tolerance in both men and women, including elderly patients, with CHD and with heart failure. This functional improvement occurs without significant cardiovascular complications or other adverse outcomes. Appropriately prescribed and conducted exercise training should be an integral component of cardiac rehabilitation services and particularly benefits patients with decreased exercise tolerance. Maintenance of exercise training is required to sustain improvement in exercise tolerance.

### Improvement in Symptoms

Cardiac rehabilitation exercise training decreases symptoms of angina pectoris in patients with CHD and decreases symptoms of heart failure in patients with left ventricular systolic dysfunction. Improvement in clinical measures of myocardial ischemia, as identified by electrocardiographic (ECG) and nuclear cardiology techniques, following exercise rehabilitation provides objective support for the reported symptomatic improvement. Exercise training of patients with left ventricular systolic dysfunction provides added symptomatic improvement to that achieved by appropriate medication management.

### Improvement in Blood Lipid Levels

Multifactorial cardiac rehabilitation in patients with CHD, including exercise training and education, results in improved lipid and lipoprotein levels. Exercise training as a sole intervention has not effected consistent improvement in lipid profiles. Optimal lipid management requires specifically directed dietary and, when medically indicated, pharmacologic management as a component of multifactorial cardiac rehabilitation.

### Reduction in Cigarette Smoking

Multifactorial cardiac rehabilitation, with well-designed educational and behavioral components, reduces cigarette smoking. Sixteen to 26 percent of patients can be expected to stop smoking. These smoking cessation rates enhance the spontaneously high smoking cessation rates in most populations following a coronary event. Scientific evidence, consensus reports, and scientific reviews in the nonrehabilitation setting, including the Surgeon General's messages since 1965, lend strong support that education, counseling, and behavioral interventions are beneficial for smoking cessation.

### Improvement in Psychosocial Well-Being and Stress Reduction

Exercise training enhances measures of psychological and social functioning, particularly as a component of multifactorial cardiac rehabilitation. Improvement in psychological status and functioning, including measures of emotional stress and reduction of the Type-A behavior pattern, is consistent with the improvement in psychosocial outcomes that occurs in nonrehabilitation settings.

### Reduction in Mortality

A survival benefit for patients who participate in cardiac rehabilitation exercise training is suggested from the scientific data, but this cannot be attributed solely to exercise training because many studies involved multifactorial interventions. Meta-analysis of the randomized controlled trials of exercise rehabilitation in patients following myocardial infarction establishes a reduction in mortality approximating 25 percent at 3-year followup. This reduction in mortality approaches that resulting from pharmacologic management of patients following myocardial infarction with beta-blocking drugs or patients with left ventricular systolic dysfunction with angiotensin-converting enzyme (ACE) inhibitor therapy. The reduction in cardiovascular mortality was 26 percent in multifactorial randomized trials of cardiac rehabilitation and 15 percent in trials that involved only an exercise intervention. The panel concludes that multifactorial cardiac rehabilitation services can reduce mortality in patients following myocardial infarction.

### Safety

The safety of cardiac rehabilitation exercise training is inferred from aggregate analysis of clinical experience. None of the more than three dozen randomized controlled trials of cardiac rehabilitation exercise training in patients with CHD, involving over 4,500 patients, described an increase in morbidity or mortality in rehabilitation compared with control patient groups. A survey of 142 cardiac rehabilitation programs in the United States, involving patients participating in exercise rehabilitation from 1980 to 1984, reported, based on aggregate data, a low rate of nonfatal myocardial infarction of 1 per 294,000 patient-hours; the cardiac mortality rate was 1 per 784,000 patient-hours. A total of 21 episodes of cardiac arrest occurred, with successful resuscitation of 17 patients. Thus, the safety of exercise rehabilitation is established by the very low rates of occurrence of myocardial infarction and cardiovascular complications during exercise training.

## Intake Assessment, Risk Stratification, and Transition Planning

Authoritative, detailed documents addressing the organizational structure, delivery, and management approaches to cardiac rehabilitation services have been published by the American College of Cardiology (ACC), the American College of Physicians (ACP), the American Heart Association (AHA), and the American Association of Cardiovascular and Pulmonary Rehabilitation (AACVPR). This Clinical Practice Guideline does not duplicate this information. The panel highlights the value of risk stratification of patients with CHD as a basis for individual prescription of exercise training and appropriate exercise supervision. Risk stratification is based on clinical assessment of functional capacity, myocardial ischemia, ventricular dysfunction, and arrhythmias. The panel agrees with a 1988 report of the U.S. Department of Health and Human Services (U.S. DHHS) regarding ECG monitoring during cardiac rehabilitation exercise training that "given the variable occurrence of arrhythmias and the fact that the safety of exercise regimens has only been documented by means of aggregate data, the use of continuous or intermittent monitoring for a specific patient remains a matter of clinical judgement." The initial assessment of a patient should incorporate the patient's educational and psychosocial status as a basis for recommending interventions.

In recent years, alternate approaches to the delivery of cardiac rehabilitation services, other than traditional supervised group and individual programs, have been examined in carefully selected, clinically stable patients. These alternate approaches, often home-based, can be effectively and safely implemented for such patients. Transtelephonic and other means of monitoring and surveillance of low- and moderate-risk patients can extend cardiac rehabilitation services beyond the traditional supervised setting and broaden the availability of cardiac rehabilitation services.

## Conclusions

On the basis of a comprehensive review of the scientific literature, the panel concludes that cardiac rehabilitation services are an essential component of the contemporary management of patients with multiple presentations of CHD and with heart failure. Cardiac rehabilitation is a multifactorial process that includes exercise training, education, counseling regarding risk reduction and lifestyle changes, and use of behavioral interventions; these services should be integrated into the comprehensive care of cardiac patients. The objectives of cardiac rehabilitation services are to improve both the physiologic and psychosocial status of cardiac patients. The physiologic outcomes targeted include improvement in exercise capacity and exercise habits and optimization of risk-factor status, including improvement in blood lipid and lipoprotein profiles, body weight, and blood glucose and blood pressure levels, and the cessation of smoking. Enhancement of myocardial perfusion and performance, as well as reduction in progression of the underlying atherosclerotic process, are additional goals. The psychosocial functioning of patients should be improved when needed, including reduction of stress, anxiety, and depression. Functional independence of patients, particularly the elderly, is an essential goal of cardiac rehabilitation services. Return to appropriate and satisfactory work could benefit both patients and society.

## Recommendations for Additional Research

Further scientific studies should address the following:

- Evaluation of the effects of cardiac rehabilitation exercise training, education, counseling, and behavioral interventions on special populations. These populations include elderly patients, women of all ages, patients from different ethnic groups, and those with lower educational or socioeconomic levels.
- Examination of outcomes of cardiac rehabilitation services in patients following acute myocardial infarction treated with contemporary therapies, including coronary thrombolysis and acute angioplasty.
- Evaluation of the effects of cardiac rehabilitation on rates of return to work, specifically targeting vocational rehabilitation counseling as a cardiac rehabilitation service.
- Evaluation of cost-effectiveness and cost-outcomes resulting from the delivery of cardiac rehabilitation services. A comparison should be made between various modes of delivery of cardiac rehabilitation services.
- Evaluation of outcomes of exercise rehabilitation with and without supervision and with and without ECG monitoring and surveillance in patients from higher risk groups including those with heart failure, elderly patients, and those with complex cardiovascular disease.
- Identification of factors that enhance adherence to cardiac rehabilitation services, including risk reduction and behavioral interventions.
- Evaluation of the safety and efficacy of strength training in higher risk populations such as elderly patients, women, unfit cardiac patients, and others at moderate-to-high cardiovascular risk.
- Prospective evaluation of the safety and benefit of exercise rehabilitation in patients with compensated heart failure and impaired ventricular systolic function.
- Development of optimal education and counseling strategies for cost-effective coronary risk reduction.
- Development and assessment of valid psychosocial measures to ascertain improvement in psychological functioning and quality of life in patients following participation in multifactorial cardiac rehabilitation.
- Development of behavioral interventions for lifestyle changes for use in large populations of coronary patients, with prospective evaluation of gender, age, and ethnic differences in outcomes.