# Acknowledgments

This Clinical Practice Guideline is the culmination of commitment, expertise, and concern on the part of many individuals.

The panel appreciates the steadfast support and guidance provided by Carole Hudgings, PhD, RN, the AHCPR project officer for most of the guideline development, and by Ernestine W. Murray, RN, MAS, the subsequent project officer.

George Sopko, MD, of the National Heart, Lung, and Blood Institute, provided invaluable clinical and administrative expertise, encouragement, and support to the panel throughout the deliberation and decisionmaking process.

The methodologist for this guideline, Steven H. Woolf, MD, MPH, educated the panel in the essentials of guideline development. His knowledge was essential in establishing the guideline process during the project's first year.

The panel also acknowledges the understanding and support of Pat Comoss, RN, who served as liaison on behalf of the American Association of Cardiovascular and Pulmonary Rehabilitation. She carried out her demanding responsibilities with exceptional patience, grace, and understanding.

The invaluable role of the peer reviewers is also acknowledged. Their clear and detailed critical review of the guideline document, on two separate occasions, greatly enhanced the final product.

The panel is particularly grateful to the untiring dedication of the project office staff: Dorothy B. Seidman, Julie Piech, and Mariette Chagnon, MS.