# Dedication

This guideline is dedicated to our wonderful panel member, the late Helen Gaston. Helen was a special person, and her loss is inestimable. As a participant in cardiac rehabilitation services, Helen was a believer in the value of cardiac rehabilitation. She served as an inspiration to hundreds of patients involved in cardiac rehabilitation.

Helen provided culturally sensitive insight as both an educator and a consumer of cardiac rehabilitation services. Her contributions to the development of this Clinical Practice Guideline, although tragically cut short, were of unique and invaluable benefit.