# Panel

- Nanette Kass Wenger, MD
- Panel Co-Chair
- Professor of Medicine (Cardiology)
- Emory University School of Medicine
- Consultant, Emory Heart Center
- Atlanta, Georgia
- Cardiologist
- Erika Sivarajan Froelicher, RN, PhD
- Panel Co-Chair
- Professor
- Department of Physiological Nursing
- School of Nursing and Adjunct Professor
- Department of Epidemiology and Biostatistics
- School of Medicine
- University of California, San Francisco
- San Francisco, California
- Cardiovascular Nurse
- Philip A. Ades, MD
- Director, Cardiac Rehabilitation Associate Professor
- University of Vermont College of Medicine
- Burlington, Vermont
- Cardiologist
- Kathy Berra, BSN (Subcommittee Chair)
- Clinical Trials Director
- Stanford Center for Research in Disease Prevention
- Palo Alto, California
- Cardiovascular Nurse
- James A. Blumenthal, PhD (Subcommittee Chair)
- Director, Behavioral Medicine Program
- Center for Living
- Duke University Medical Center
- Durham, North Carolina
- Clinical Psychologist
- Catherine M. E. Certo, ScD, PT
- Associate Professor
- Boston University
- Sargent College of Allied Health Professions
- Boston, Massachusetts
- Physical Therapist/Exercise Physiologist
- Anne M. Dattilo, PhD, RD
- Assistant Professor
- Department of Nutrition
- University of Georgia
- Athens, Georgia
- Dietitian
- Dwight Davis, MD
- Director, Cardiac Rehabilitation Program
- Professor of Medicine
- University Hospital
- The Milton S. Hershey Medical Center
- Hershey, Pennsylvania
- Cardiologist
- Robert F. DeBusk, MD (Subcommittee Chair)
- Professor of Medicine
- Stanford University School of Medicine
- Palo Alto, California
- Cardiologist
- Joseph P. Drozda, Jr., MD
- Chief of Cardiology and Medical Director of the Cardiac Rehabilitation Program
- DePaul Health Center
- St. Louis, Missouri
- Cardiologist
- Barbara J. Fletcher, RN, MN
- Director of Research
- Emory Health Enhancement Program
- Emory University
- Atlanta, Georgia
- Cardiovascular Nurse
- Barry A. Franklin, PhD (Subcommittee Chair)
- Director, Cardiac Rehabilitation and Exercise Laboratories
- William Beaumont Hospital
- Royal Oak, Michigan
- Exercise Physiologist
- Helen Gaston (deceased)
- Tempe, Arizona
- Consumer Representative
- Primary Care, Community Health
- Philip Greenland, MD (Subcommittee Chair)
- Harry W. Dingman Professor of Cardiology
- Chair, Department of Preventive Medicine
- Northwestern University Medical School
- Chicago, Illinois
- Cardiologist
- Patrick E. McBride, MD, MPH
- Associate Professor
- Department of Family Medicine and Medicine-Cardiology
- University of Wisconsin-Madison
- Madison, Wisconsin
- Family Physician
- Christopher G. A. McGregor, MB, FRCS
- Mayo Clinic
- Rochester, Minnesota
- Cardiothoracic Surgeon
- Neil B. Oldridge, PhD (Subcommittee Chair)
- Professor of Health Sciences
- University of Wisconsin-Milwaukee
- Milwaukee, Wisconsin
- Exercise Physiologist
- Joseph C. Piscatella
- President
- Institute for Fitness and Health, Inc.
- Tacoma, Washington
- Consumer Representative
- Felix J. Rogers, DO
- Downriver Cardiology Consultants
- Trenton, Michigan
- Cardiologist

## Consultants

- William Johnson, PhD
- Professor of Health Economics
- School of Health Administration and Policy
- Arizona State University
- Tempe, Arizona
- Health Policy Analyst
- Jennie J. Kronenfeld, PhD
- Professor
- School of Health Administration and Policy
- Arizona State University
- Tempe, Arizona
- Health Policy Analyst
- Steven H. Woolf, MD, MPH
- Assistant Clinical Professor
- Department of Family Practice
- Medical College of Virginia
- Fairfax, Virginia
- Methodologist

## Project Staff

- L. Kent Smith, MD, MPH
- Director, Cardiac Rehabilitation
- Arizona Heart Institute
- Phoenix, Arizona
- Project Director
- Dorothy B. Seidman
- Project Headquarters
- Phoenix, Arizona
- Project Manager
- Mariette Chagnon, MS
- Project Headquarters
- Phoenix, Arizona
- Literature Assistant
- Pat Comoss, RN, BS
- Chair
- AACVPR Project Oversight Committee
- Harrisburg, Pennsylvania
- Nurse Consultant, Cardiac Rehabilitation
- Julie Piech
- Project Headquarters
- Phoenix, Arizona
- Project Assistant