# Foreword

Cardiovascular disease is the leading cause of morbidity and mortality in the United States, responsible for almost 50 percent of all deaths. Coronary disease, the major category of cardiovascular disease, is clinically manifest as stable angina pectoris, unstable angina pectoris, myocardial infarction, silent myocardial ischemia, and sudden death. More than 13.5 million Americans have a history of myocardial infarction or experience angina pectoris. Nearly 1.5 million Americans sustain myocardial infarction each year, of which almost 500,000 are fatal. Five percent of myocardial infarctions occur in people younger than age 40, and about 45 percent occur in people under age 65. About 55 percent of all acute myocardial infarctions occur in the Medicare age group.

The almost 1 million survivors of myocardial infarction are potential candidates for cardiac rehabilitation services, as are the more than 7 million patients with stable angina pectoris and patients following revascularization with coronary artery bypass surgery (309,000 patients in 1993, 45 percent under age 65), and percutaneous transluminal coronary angioplasty and other transcatheter interventional procedures (362,000 in 1993, 54 percent under age 65). Of these several million patients with coronary disease who are candidates for cardiac rehabilitation services, only 11-38 percent of patients typically participate in cardiac rehabilitation programs.

Another major cardiac problem -- heart failure -- is the most common discharge diagnosis for hospitalized Medicare patients and the fourth most common discharge diagnosis for all patients hospitalized in the United States. The prevalence of heart failure has increased steadily with aging of the U.S. population and with the improved rate of survival resulting from the use of newer therapies for cardiovascular diseases. Many patients with end-stage heart failure are candidates for cardiac transplantation surgery. As benefits and safety are documented, cardiac rehabilitation services for patients with heart failure and after cardiac transplantation have gained increasing acceptance.

This Clinical Practice Guideline was developed under a contract from Agency for Health Care Policy and Research with the support of the National Heart, Lung, and Blood Institute. The contract was awarded to the American Association of Cardiovascular and Pulmonary Rehabilitation, which convened a private-sector multidisciplinary panel of experts that included physicians (cardiologists, internists, family physicians, and cardiac surgeons), registered nurses, a clinical health psychologist, a registered dietitian, exercise physiologists, a physical therapist, and two consumer-patient members -- collectively referred to in this document as "the panel." The panel principally based the conclusions and recommendations in this guideline on scientific evidence from an extensive review of original research published in peer-reviewed medical and health sciences journals. This guideline addresses the role of cardiac rehabilitation services for adult patients with coronary disease, with heart failure, and after cardiac transplantation.

This guideline is designed to assist health care practitioners and consumers in making more informed decisions about their choices and to inform them of the cost-effectiveness of cardiac rehabilitation services. Needs for additional research are also highlighted.