# Effects of Cardiac Rehabilitation Education, Counseling, and Behavioral Interventions

In this guideline, "education" is defined as systematic instruction, and "counseling" is defined as providing advice, support, and consultation. "Behavioral interventions" refer to systematic instruction in techniques to modify health-related behaviors.

This chapter discusses the effects of cardiac rehabilitation education, counseling, and behavioral interventions on smoking, lipids, body weight, blood pressure, exercise tolerance, symptoms, return to work, stress and psychological well-being, morbidity, and mortality.

## Smoking

RECOMMENDATION: A combined approach of education, counseling, and behavioral interventions in cardiac rehabilitation results in smoking cessation and relapse prevention and is recommended for cardiac risk reduction.

### Scientific Evidence (Strength of Evidence = B)

Seven reports in the cardiac rehabilitation literature focused on education, counseling, and behavioral interventions designed to reduce cigarette smoking. Five were randomized controlled trials (DeBusk, Houston Miller, Superko, et al., 1994; Engblom, Hietanen, Hamalainen, et al., 1992; Heller, Knapp, Valenti, et al., 1993; Sivarajan, Newton, Almes, et al., 1983; Taylor, Houston-Miller, Killen, et al., 1990), one was a nonrandomized controlled study Ben-Ari, Rothbaum, Linnemeier, et al., 1992), and one was an observational report ( Monpere, Francois, Brochier, et al., 1988). The randomized controlled trials are summarized in Table 9. A randomized controlled trial in patients after myocardial infarction compared an exercise-only group, an exercise plus education/counseling group, and a control group. At the 3- and 6-month followups after hospital discharge, no significant differences were noted among the three groups in self-reported smoking cessation or smoking reduction to 10 or fewer cigarettes (Sivarajan, Newton, Almes, et al., 1983). A second randomized controlled trial evaluated the effects of a nurse-managed educational-behavioral intervention on smoking cessation after acute myocardial infarction Taylor, Houston-Miller, Killen, et al., 1990). This study was initiated in the hospital, and the intervention was maintained thereafter primarily through telephone contact. At the 12-month followup, significant reduction in biochemically verified smoking cessation occurred in intervention patients compared with control patients -- 71 percent versus 45 percent, (p = .01). A third study of multifactorial rehabilitation, which included exercise training and education, involved men under 65 years of age following CABG (Engblom, Hietanen, Hamalainen, et al., 1992); smoking at the 12-month followup was significantly lower in rehabilitation patients compared with control patients -- 12 percent versus 15 percent (p < .01). Another randomized controlled trial in patients following myocardial infarction compared informational mailings supplemented by telephone contact with the rehabilitation staff versus a control group of patients that received usual care Heller, Knapp, Valenti, et al., 1993). At the 6-month followup by questionnaire assessment, there were no significant differences in rates of cigarette smoking. The final randomized controlled trial involved men and women following myocardial infarction and compared nurse-managed home-based multifactorial cardiac rehabilitation with usual care DeBusk, Houston Miller, Superko, et al., 1994). Concurrent pharmacologic intervention with nicotine patches was reported in 10 percent of the intervention and in 2 percent of the control group. At the 12-month followup, biochemically confirmed smoking cessation rates were 70 percent in the intervention patients compared with 53 percent in the control patients, a 17 percent difference favoring the intervention group (p = .03).

Table 9. Effect of cardiac rehabilitation on smoking cessation: Randomized controlled trials

Reference, Country | Patients | Intervention, Followup | | Outcome
Sivarajan, Newton, Almes, et al. (1983) United States | Sample size: 258 Gender: 219 men, 39 women Age: 70 years and younger Category: MI | Intervention: Low-level exercise training; low-level exercise and education/counseling + eight 1-hour group education classes Followup: 3 and 6 months | | Similar percentage of smokers at baseline in all 3 groups At 3 and 6 month followup, no significant differences among the 3 groups in self-reported smoking habits
Taylor, Houston-Miller, Killen, et al. (1990) United States | Sample size: 173 (86 intervention, 87 control) Gender: 85% men Age: 70 years and younger Category: Patients after MI who had smoked tobacco within 6 months of acute event. | Intervention: Nurse-directed smoking cessation behavioral approach and education begun 1 day after transfer from CCU, supplemented by printed and audiotape material. Nicotine gum for 5 patients refractory to behavioral technique. Followup telephone contact for 4 months after discharge. Followup: 26 and 52 weeks | | Biochemically documented smoking cessation: 71% intervention group, 45% usual care; 26% difference between groups (p = .01)
Engblom, Hietanen, Hamalainen, et al. (1992) Finland | Sample size: 228 Gender: 81% men Age: 65 years and younger, mean 54 years Category: CABG | Intervention: 3 week rehabilitation 6-8 weeks following CABG. 5 hours nutrition advice, supervised exercise (21 total hours). No specific smoking cessation intervention other than physician advice to stop smoking during risk factor education classes. Followup: 6 and 12 months | | 12 months: Significant decrease in self-reported smoking: 12% rehabilitation, 15% control (p = .01)
Heller, Knapp, Valenti, et al. (1993) Australia | Sample size: 450 (213 intervention, 237 control) Gender: 76% men intervention, 68% men control Age: 70 years and younger Category: Suspected MI | Intervention: 3 sets of educational materials mailed to patients in initial 8 weeks after hospital discharge emphasizing diet, exercise, and smoking cessation supplemented by 2 telephone calls from program office Followup: 6 months | | Self-report: Current smoking: 11% intervention, 13% usual care No significant difference between groups
DeBusk, Houston Miller, Superko, et al. (1994) United States | Sample size: 585 (293 intervention, 292 usual care) Gender: 79% men Age: 70 years and younger, mean 57 years Category: MI | Intervention: Lipid-lowering medications if LDL cholesterol < 95 mg/dL at day 90. Initial nutrition counseling (NCEP Step II diet). Smoking cessation initiated by MD-smoking message + relapse prevention manual and relaxation audiotape. Nicotine gum for highly addicted patients who relapsed. Followup: 6 and 12 months | | Biochemically verified 6-month smoking cessation rates: 69% intervention, 55% control; 14% difference between groups (not significantly different) Biochemically verified 1-year smoking cessation rates: 70% intervention, 53% control; 17% difference between groups (p = .03)

Note: CABG = coronary artery bypass graft surgery; CCU = cardiac care unit; LDL = low- density lipoprotein; MD = physician; MI = myocardial infarction; NCEP = National Cholesterol Education Program.

A nonrandomized controlled trial in patients following PTCA compared multifactorial exercise and education-counseling versus usual care. Self-reported smoking cessation differences between intervention and control patients were 18 percent at both the 3-and 18-month followups (p < .01) (Ben-Ari, Rothbaum, Linnemeier, et al., 1992). A single observational study described a self-reported smoking reduction from 59 percent to 7 percent (Monpere, Francois, Brochier, et al., 1988).

### Conclusions

Well-designed education and behavioral interventions (relapse prevention) reduce cigarette smoking. Between 17 and 26 percent of patients can be expected to stop smoking ( DeBusk, Houston Miller, Superko, et al., 1994; Taylor, Houston-Miller, Killen, et al., 1990). These findings supplement prior reports on the spontaneously high cessation rates in most populations soon after myocardial infarction DeBusk, Houston Miller, Superko, et al., 1994; Sivarajan, Newton, Almes, et al., 1983). One effective model includes nurse-managed smoking cessation-behavioral intervention with biochemical verification of smoking status. Whether biochemical verification should be recommended for clinical practice is unclear. Scientific evidence, consensus papers, and other scientific reviews in nonrehabilitation settings, including the Surgeon General's messages since 1965, lend strong support that education, counseling, and behavioral interventions are beneficial for smoking cessation Centers for Disease Control and Prevention, 1992; Cohen, Lichenstein, Prochaska, et al., 1989; Fiore, Novotny, Pierce, et al., 1990; U.S. Preventive Services Task Force, 1989).

## Lipids

RECOMMENDATION: Intensive nutritional education, counseling, and behavioral interventions improve dietary fat and cholesterol intake. Education, counseling, and behavioral interventions about nutrition -- with and without pharmacologic lipid-lowering therapy -- result in significant improvement in blood lipid levels and are recommended as components of cardiac rehabilitation.

### Scientific Evidence (Strength of Evidence = B)

Eighteen reports provided information on the effect of education, counseling, and behavioral intervention, either alone or as part of multifactorial cardiac rehabilitation, on dietary change, and/or blood lipid levels. Twelve were randomized controlled trials (Barnard, Scherwitz, and Ornish, 1992; DeBusk, Houston Miller, Superko, et al., 1994; Engblom, Hietanen, Hamalainen, et al., 1992; Friedman, Thoresen, Gill, et al., 1986; Haskell, Alderman, Fair, et al., 1994; Heller, Knapp, Valenti, et al., 1993; Karvetti and Hamalainen, 1993; Ornish, Brown, Scherwitz, et al., 1990; Ornish, Scherwitz, Doody, et al., 1983; Rahe, Ward, and Hayes, 1979; Schuler, Hambrecht, Schlierf, et al., 1992a; Schuler, Hambrecht, Schlierf, et al., 1992b; Sivarajan, Newton, Almes, et al., 1983); these are described in Table 10. Three were nonrandomized controlled studies ( Adsett and Bruhn, 1968; Ben-Ari, Rothbaum, Linnemeier, et al., 1992; Ribiero, Hartley, Sherwood, et al., 1984), and three were observational reports Monpere, Francois, Brochier, et al., 1988; Smith, Layton, Newmark, et al., 1987; Wrisley and Rubenfire, 1988).

Table 10. Effect of cardiac rehabilitation on lipid outcomes: Randomized controlled trials

Reference, Country | Patients | Intervention, Followup | | Outcome (values in mg/dL)
Ward, and Hayes (1979) United States | Sample size: 44 (22 group therapy, 22 control) Gender: 3 females group therapy, 1 control group Age: 60 years and younger, mean age 51 group therapy, 55 control Category: MI | Intervention: Every other week group therapy for 90 minutes, beginning 1 month after hospital discharge for 4 sessions. 1 session with patient and spouse, all other sessions spouse only. Main approach: Education and discussion on coronary risk behaviors and their modification. Followup: 3-4 years | | No significant difference in lipid levels between groups
Sivarajan, Newton, Almes, et al. (1983) United States | Sample size: 258 (88 exercise only, 86 exercise and teaching/counseling + group education, 84 control) Gender: 219 men, 39 women Age: 70 years and younger, mean age 56 Category: MI | Intervention: Low-level exercise training. Low-level exercise training and education/counseling + eight 1-hour group education/counseling classes. Followup: 3 and 6 months | | Dietary cholesterol, saturated fat, and sodium intake scores significantly improved in both groups without significant difference between groups, compared with control group Serum lipid levels not reported
Ornish, Scherwitz, Doody, et al. (1983) United States | Sample size: 46 (27 intervention, 19 control) Gender: Not specified Age: Range 45-75 years Category: Stable CHD documented by catheterization | Intervention: Residential program 24 days. 5 hours/day of stress management, vegetarian diet, 3 hours/week of exercise, 2 times weekly social support group meetings. Followup: 24 days | | Total cholesterol and triglyceride levels: Significant decrease intervention vs. control HDL: Significantly decreased in intervention group from baseline (47.1 to 39. 2); no change in HDL in control. (p < .001).
Friedman, Thoresen, Gill, et al. (1986) United States | Sample size: 946 (270 cardiac counseling, 592 cardiac counseling + Type-A behavioral counseling, 84 control) Gender: Not specified Age: 64 years and younger, mean 53 years Category: At least 6 months following MI | Intervention: Cardiac counseling for 22 sessions, 90 minutes/session for 3 years for information on diet, exercise, and medication. 1 session every 3 months with psychiatrist or psychologist for general information. Type-A behavioral counseling group received instruction on progressive muscle relaxation, behavioral learning, and cognitive-affective learning. Followup: 3 years | | Mean cholesterol level decreased significantly in both groups, without significant difference between groups at 1-, 2-, and 3-year followups
Ornish, Brown, Scherwitz, et al. (1990) United States | Sample size: 41 (22 intervention, 19 control) Gender: 88% men Age: 56-60 years, mean 56 years Category: Catheterization-documented CHD | Intervention: "Lifestyle intervention." Strict diet served (10% calories fat, 20% protein, 70% complex carbohydrate, and 5 mg cholesterol). Stress management 1 hour/day with progressive relaxation/meditation. Individual exercise 50-80% maximal exercise test heart rate, 3 hours/week 30 minutes/session vs. usual care. Followup: 1 year | | Dietary fat, cholesterol intake: Significantly decreased intervention vs. control (p < .0001) Total cholesterol: Decreased 24.3% in intervention group LDL cholesterol: 37.4% in intervention group HDL cholesterol: No significant change either group Apolipoprotein B: Decreased in intervention group without change in control Apolipoprotein a1: Neither group had significant changes
Engblom, Hietanen, Hamalainen, et al. (1992) Finland | Sample size: 201 Gender: 88% men Age: 65 years and younger, mean 54 years Category: CABG | Intervention: Supervised exercise for 3 weeks, total 21 hours at intensity of 70% peak exercise test heart rate. Regular group discussions regarding diet and all risk factors. Goal set to lower cholesterol intake to < 300 mg/day and increase fiber intake. Followup: 12 months | | Total cholesterol and triglyceride levels decreased significantly from baseline to 6 and 12 months both groups. No significant difference between groups. HDL increased significantly in intervention but not in control groups. Difference between groups not significant. Ratio total:HDL cholesterol decreased significantly in both groups with greater change intervention vs. control at 6 months but not at 12 months
Schuler, Hambrecht, Schlierf, et al. (1992b) Germany | Sample size: 92 Gender: 100% men Age: Mean 53 years Category: Catheterization-documented stable CHD | Intervention: Multifactorial. Exercise, strict diet, no specific smoking cessation described. Followup: 1 year | | Intervention group decreased: Total cholesterol 10%, LDL 8%, triglycerides 24%, (p < .002 for all changes) Intervention group increased: HDL 3% (not significant) Control group lipoprotein levels unchanged, except decrease in triglyceride 17% (p < .02)
Barnard, Scherwitz, and Ornish (1992) United States | Sample size: 47 (27 intervention, 20 control) Gender: 88% men Age: 56-60 years, mean 56 years Category: Catheterization-documented CHD | Intervention: "Lifestyle intervention." Strict diet (10% calories fat, 20% protein, 70% complex carbohydrate, and 5 mg cholesterol). Stress management 1 hour or more/day with progressive relaxation and meditation. Individual exercise 50-80% of maximal exercise test heart rate, 3 hours/week, 30 minutes/sessions. Followup: 1 year | | 3-day dietary history: Significant mean decrease in intervention patients in grams of fat/day from 71 to 14; % fat calories 31 to 7; dietary cholesterol 234 to 16 mg. No significant changes in control; p < .0001 between groups. Mean total cholesterol: Intervention group 229 to 178, control 247 to 229, p < .05 between groups Mean LDL cholesterol: Intervention group 151 to 102, control 167 to 157, p < .018 between groups Mean HDL/cholesterol: No significant difference between groups Triglyceride: No significant difference between groups Dietary acceptability scores: Not significantly different between groups
Heller, Knapp, Valenti, et al. (1993) Australia | Sample size: 450 (213 intervention, 237 control) Gender: 76% men intervention, 68% men control Age: 70 years and younger, mean 59 years Category: Suspected MI | Intervention: 3 sets of educational materials mailed to patients in initial 8 weeks after hospitalization emphasizing diet, exercise, and smoking cessation. Supplemented by 2 telephone calls from program office. Followup: 6 months | | Mean fat scores by questionnaire assessment: Significantly decreased in intervention vs. usual care (p = .002) Total cholesterol: Not significantly different (mean 222 vs. 217 intervention vs. usual care) HDL cholesterol: Not significantly different (mean 44.1 intervention vs. 42.5 usual care)
Karvetti and Hamalainen (1993) Finland | Sample size: 84 (47 intervention, 37 control) Gender: All men Age: 65 years and younger; mean 52 years intervention, 53 years control Category: MI | Intervention: Multifactorial. Initial 3-4 weeks following MI included antismoking and psychological counseling. Dietary education classes and individual counseling to decrease fat calories < 30%, decrease sugar, salt, and cholesterol in diet, increase low-fat foods and vegetables. Weight decrease when appropriate. Intensive intervention first 3 months with continued intervention first 3 years. Followup: 1, 2, 6, and 10 years | | Total serum cholesterol: Significantly decreased in intervention vs. control at years 1 and 2 (p < .01) but not at years 6 and 10 Triglyceride: No significant difference at years 1, 2, 6, or 10 Lower butter consumption at year 10 Higher consumption low-fat milk years 1 and 2 Lower consumption of sugar and sweets year 1 Lower intake of fats years 1, 2, 6, and 10 Decrease in % fat calories years 1, 2, 6, and 10 Lower intake saturated fatty acids year 1 Lower intake of cholesterol at year 1 Difference favoring intervention vs. control (p < .05 for all comparisons)
DeBusk, Houston Miller, Superko, et al. (1994) United States | Sample size: 585 Gender: 79% men Age: < 70 years, mean age 57 Category: MI | Intervention: Intensive multifactorial risk reduction with home exercise training and lipid-lowering drugs when indicated Followup: 1 year | | Cholesterol, saturated fat scores: Decreased significantly over time in both groups. No significant difference between groups. Mean total cholesterol: Intervention 208 to 185, control 203 to 209, p < .001 between groups Mean LDL cholesterol: Intervention 140 to 107, control 136 to 132, p < .001 between groups No significant difference between groups in HDL cholesterol or triglyceride
Haskell, Alderman, Fair, et al. (1994) United States | Sample size: 300 Gender: 83% men intervention, 92% men usual care Age: < 75 years, mean 57 years Category: Catheterization-documented CHD including CABG, PTCA | Intervention: Home rehabilitation. Multifactorial risk reduction + lipid-lowering medications. Individual therapy guided by nurse manager including diet intervention, behavioral management for smoking cessation, and lipid-lowering medication. Individual home exercise training with transtelephonic ECG monitoring. Followup: 4 years | | Significant reduction in dietary fat, saturated fat, cholesterol intake intervention vs. control (p = .0001) Mean total cholesterol: Intervention 232 to 193, control 228 to 224, p = .001 between groups Mean LDL cholesterol: Intervention 159 to 120, control 155 to 151, p = .001 between groups Mean HDL cholesterol: Intervention 46.1 to 51.5, control 42.3 to 44.9, p = .001 between groups Triglyceride: Intervention 156 to 126, control 155 to 156, p = .002 between groups

Note: CABG = coronary artery bypass graft surgery; CHD = coronary heart disease; ECG = electrocardiographic; HDL = high-density lipoprotein; LDL = low-density lipoprotein; MI = myocardial infarction; PTCA = percutaneous transluminal coronary angioplasty.

Seven of the 12 randomized controlled trials reported changes in measures of dietary fat and cholesterol intake. Five of these seven studies reported statistically significant differences favoring intervention groups compared with control groups Barnard, Scherwitz, and Ornish, 1992; Haskell, Alderman, Fair, et al., 1994; Heller, Knapp, Valenti, et al., 1993; Karvetti and Hamalainen, 1993; Ornish, Brown, Scherwitz, et al., 1990); two reported no significant differences between groups, although significant improvements in dietary variables occurred in both groups compared with baseline (DeBusk, Houston Miller, Superko, et al., 1994; Sivarajan, Newton, Almes, et al., 1983). Eleven of the 12 randomized controlled trials reported changes in various lipid or lipoprotein serum levels. Favorable changes in lipid or lipoprotein levels in intervention patients compared with control patients occurred in seven randomized controlled trials (Barnard, Scherwitz, and Ornish, 1992; DeBusk, Houston Miller, Superko, et al., 1994; Haskell, Alderman, Fair, et al., 1994; Karvetti and Hamalainen, 1993; Ornish, Brown, Scherwitz, et al., 1990; Ornish, Scherwitz, Doody, et al., 1983; Schuler, Hambrecht, Schlierf, et al., 1992b); no significant changes were reported in four (Engblom, Hietanen, Hamalainen, et al., 1992; Friedman, Thoresen, Gill, et al., 1986; Heller, Knapp, and Valenti, 1993; Rahe, Ward, and Hayes, 1979).

Three nonrandomized controlled trials reported changes in lipid levels (Adsett and Bruhn, 1968; Ben-Ari, Rothbaum, Linnemeier, et al., 1992; Ribiero, Hartley, Sherwood, et al., 1984). One reported significant improvements in lipid values when dietary education and counseling plus exercise was compared with exercise alone in patients with CHD Ribiero, Hartley, Sherwood, et al., 1984). The two other nonrandomized controlled trials reported no significant difference between intervention and control groups Adsett and Bruhn, 1968; Ben-Ari, Rothbaum, Linnemeier, et al., 1992). Two of the three observational studies ( Monpere, Francoise, Brochier, et al., 1988; Smith, Layton, Newmark, et al., 1987) reported significant improvement in lipid levels compared with baseline, and one reported no change (Wrisley and Rubenfire, 1988).

### Conclusions

Efficacy of intensive nutritional education, counseling, and behavioral interventions on dietary fat intake and blood lipid levels is also documented in noncardiac rehabilitation settings. Results from a meta-analysis of 70 studies indicate that weight reduction through dietary modification can help normalize plasma lipid and lipoprotein levels in overweight individuals Dattilo and Kris-Etherton, 1992). The NCEP II recommended an LDL cholesterol goal of less than 100 mg/dL National Cholesterol Education Program, 1993). Intensive interventions in studies from nonrehabilitation settings provide strong evidence for efficacy of dietary intervention Blankenhorn, Nessim, Johnson, et al., 1987; Brown, Albers, Fisher, et al., 1990; Buchwald, Varco, Matts, et al., 1990; Kane, Mallory, Ports, et al., 1990; Nau, Katch, and Tsai, 1991). In many patients, pharmacologic therapy may be required in addition to dietary and exercise management to achieve this goal. Thus, independent effects of education and counseling may be impossible to ascertain. Success as defined in the NCEP II guidelines requires high-intensity intervention that includes education, counseling, behavioral intervention, and adherence and motivational strategies as well as pharmacologic therapy for appropriate patients National Cholesterol Education Program, 1993).

## Body Weight

RECOMMENDATION: Multifactorial rehabilitation that combines dietary education, counseling, and behavioral interventions designed to reduce body weight can help patients lose weight. Education as a sole intervention is unlikely to achieve and maintain weight loss. These multifactorial cardiovascular risk-reduction interventions are recommended as components of comprehensive cardiac rehabilitation.

### Scientific Evidence (Strength of Evidence = B)

Five reports ( Dracup, Meleis, Clark, et al., 1984; Haskell, Alderman, Fair, et al., 1994; Karvetti and Hamalainen, 1993; Monpere, Francois, Brochier, et al., 1988; Sivarajan, Newton, Almes, et al., 1983) addressed changes in body weight as a result of cardiac rehabilitation education, counseling, and behavioral interventions. Three were randomized controlled trials in a rehabilitation setting (Haskell, Alderman, Fair, et al., 1994; Karvetti and Hamalainen, 1993; Sivarajan, Newton, Almes, et al., 1983), one of which was a home-based, alternate strategy for cardiac rehabilitation (Karvetti and Hamalainen, 1993). One was a nonrandomized controlled study Dracup, Meleis, Clark, et al., 1984) and one an observational report ( Monpere, Francois, Brochier, et al., 1988).

One randomized controlled trial reported no significant differences in weight loss at the 3- and 6-month followups in a comparison of three groups: exercise training alone; exercise training plus education/counseling (these classes took place in a group setting); and control patients ( Sivarajan, Newton, Almes, et al., 1983). A second randomized controlled trial in patients after myocardial infarction reported significant reduction in mean body weight in the intervention group compared with the control group at 1-10 years of followup Karvetti and Hamalainen, 1993). A 4-year randomized controlled trial compared multiple risk factor reduction with usual care (Haskell, Alderman, Fair, et al., 1994). A statistically significant body weight reduction of 4 percent occurred in the intervention group compared with the control group (intervention weight of 80.4 +/- 12.7 kg versus usual-care weight of 85.5 +/- 15.0 kg, p = .0001). The nonrandomized controlled trial in patients with CHD showed a significant reduction in the percentage of body fat in the counseling group versus the control group Dracup, Meleis, Clark, et al., 1984). The observational study reported reductions in body weight in overweight patients, as assessed by questionnaire, following multifactorial rehabilitation (Monpere, Francois, Brochier, et al., 1988).

### Conclusions

Education is a necessary component of a successful weight-reduction intervention but is not sufficient as a sole intervention to effect sustained weight loss. Nutritional education combined with behavioral interventions and prescribed exercise can achieve modest and sustained weight loss (Dracup, Meleis, Clark, et al., 1984). Multifactorial intervention studies have documented favorable reductions in body weight Ornish, Brown, Scherwitz, et al., 1990; Wood, Stefanick, Williams, et al., 1991). Results of meta-analysis of 70 studies indicate that weight reduction through dieting can also help normalize plasma lipid lipoprotein levels in overweight individuals Dattilo and Kris-Etherton, 1992). Steady improvement in sustained weight loss in obese patients has been documented in nonrehabilitation settings. The panel noted a review of the behavioral therapy literature involving obese patients Brownell and Jeffery, 1987). State-of-the-art weight loss programs that have been shown to be successful nonrehabilitation settings are also likely to be successful in a rehabilitation setting (Brownell and Jeffery, 1987; Dattilo and Kris-Etherton, 1992). Expert opinion agrees that multifactorial interventions to reduce weight are effective with intense education and behavioral intervention programs.

## Blood Pressure

RECOMMENDATION: Expert opinion supports education as an important component of a multifactorial education, counseling, behavioral intervention, and pharmacologic approach to the management of hypertension. This approach is documented to be effective in nonrehabilitation populations and should also be included in cardiac rehabilitation. Education, counseling, and behavioral interventions as sole modalities have not been shown to control elevated blood pressure levels.

### Scientific Evidence (Strength of Evidence = B)

Two nonrandomized controlled trials evaluated the effects of education on blood pressure control (Dracup, Meleis, Clark, et al., 1984; Engblom, Hietanen, Hamalainen, et al., 1992). One reported a significant reduction in systolic blood pressure in patients with a spouse participant compared with patient-only and control groups (Dracup, Meleis, Clark, et al., 1984). The other study was unable to detect any benefit of education in reducing levels of blood pressure (Engblom, Hietanen, Hamalainen, et al., 1992). No study specifically addressed patients with hypertension.

### Conclusions

Scientific evidence suggests that education alone, in a cardiac rehabilitation setting, fails to significantly decrease blood pressure. One of the most serious flaws in study design includes the mixed sample of normotensive patients and a small proportion of hypertensive patients. Education and behavioral interventions, as outlined in JNC V (National High Blood Pressure Education Program, 1993), are important components of a multifactorial approach to reduce hypertension. The JNC V recommendations, which were based on the opinion of recognized experts in hypertension, stated that "lifestyle modification such as weight reduction, physical activity and moderation of dietary sodium are recommended as definitive or adjunctive therapy for hypertension." JNC V concluded that, based on scientific evidence and expert opinion, relaxation and biofeedback had little effect. JNC V also concluded that the scientific literature and expert opinion do not support use of stress management as a sole intervention for hypertension control. The panel recommends the application of the JNC V recommendations for the cardiac rehabilitation population.

Despite few studies in a cardiac rehabilitation setting, there is a beneficial effect from combined educational and behavioral strategies to change behavior and thereby lower blood pressure in other settings (National High Blood Pressure Education Program, 1993). Comprehensive educational programs should include information about weight management, exercise, and nutrition. The purpose of medications, their potential side effects, and strategies to improve medication adherence also should be included. Instruction in techniques of self-monitoring techniques of blood pressure is important in followup care.

## Exercise Tolerance

RECOMMENDATION: Cardiac rehabilitation education, counseling, and behavioral interventions without exercise training are unlikely to improve exercise tolerance and are not recommended for that purpose.

### Scientific Evidence (Strength of Evidence = C)

Three reports described the effect of education, counseling, and behavioral interventions on exercise tolerance Munro, Creamer, Haggerty, et al., 1988; Ornish, Scherwitz, Doody, et al., 1983; Smith, Layton, Newmark, et al., 1987). One randomized controlled trial showed a significant increase in measures of exercise tolerance following 24 days of residential multifactorial cardiac rehabilitation in patients with stable CHD (Ornish, Scherwitz, Doody, et al., 1983). One nonrandomized controlled study of men after myocardial infarction compared 27 patients taught relaxation techniques for 20 minutes twice per day with 30 control patients Munro, Creamer, Haggerty, et al., 1988). At 6, 12, and 24 weeks, there were no differences in exercise tolerance between intervention and control patients. One observational study of 50 patients with disabling CHD who were unsuitable for surgical intervention reported a significant increase in exercise duration after 8 weeks of exercise training, education, counseling, behavioral interventions, and stress management (p < .01) Smith, Layton, Newmark, et al., 1987). Without a comparison group, spontaneous improvement cannot be ruled

### Conclusions

Limited data fail to demonstrate the efficacy of education or counseling as sole interventions, independent of exercise training or other elements of cardiac rehabilitation, in improving exercise tolerance. Education, counseling, and behavioral interventions may improve morale, self-esteem, and adherence to exercise.

## Symptoms

RECOMMENDATION: Cardiac rehabilitation education, counseling, and behavioral interventions are recommended alone, or as components of multifactorial cardiac rehabilitation, to reduce symptoms of angina.

### Scientific Evidence (Strength of Evidence = B)

Four reports described changes in anginal symptoms as a result of cardiac rehabilitation education and counseling: two randomized controlled trials (Friedman, Thoresen, Gill, et al., 1986; Ornish, Scherwitz, Doody, et al., 1983), one nonrandomized controlled trial Ben-Ari, Rothbaum, Linnemeier, et al., 1992), and one observational report ( Smith, Layton, Newmark, et al., 1987).

A randomized controlled trial in coronary patients described a statistically significant decrease in the frequency of anginal episodes in the stress management intervention group Ornish, Scherwitz, Doody, et al., 1983). A second randomized controlled trial of patients at least 6 months after myocardial infarction reported significantly (p < .05) less angina at the 3- year followup in patients who received Type-A counseling compared with control patients Friedman, Thoresen, Gill, et al., 1986). A nonrandomized controlled study of patients after PTCA reported significant difference between intervention and control groups in exercise-induced angina at the 18-month followup Ben-Ari, Rothbaum, Linnemeier, et al., 1992). One observational report described significant reduction in weekly anginal episodes and nitroglycerin use after 8 weeks of multifactorial rehabilitation (Smith, Layton, Newmark, et al., 1987).

### Conclusions

Education, counseling, and behavioral interventions, either alone or as components of multifactorial cardiac rehabilitation, are associated with reduction in angina pectoris. Behavioral interventions are generally effective in reducing anginal pain. The benefit of exercise training in reducing angina is discussed in Chapter 2.

## Return to Work

RECOMMENDATION: Education, counseling, and behavioral interventions have not been shown to improve rates of return to work, which are contingent on many social and policy issues. In selected patients, formal cardiac rehabilitation vocational counseling may improve rates of return to work.

### Scientific Evidence (Strength of Evidence = C)

Three randomized controlled trials addressed the effect of cardiac rehabilitation education, counseling, and behavioral interventions on return to work and showed no statistically significant difference in return to work between intervention (education, counseling, and social interventions plus exercise training) and control groups (Bengtsson, 1983; Froelicher, Kee, Newton, et al., 1994; Hamalainen, Kallio, Knuts, et al., 1991).

### Conclusions

Multifactorial cardiac rehabilitation, including education, counseling, and behavioral interventions, has not been shown to alter the rates of return to work. Education and counseling may improve a patient's potential for return to work. Many other factors that play a significant role in return to work, including willingness of the employer to reemploy the patient, the patient's level of job satisfaction, economic incentives, and perceived stress of the job, were not evaluated in the studies cited. Better understanding (via education) of capabilities and limitations regarding work may influence a patient's self-efficacy for returning to previous employment or for seeking job retraining. A randomized controlled trial in a health maintenance organization population (a nonrehabilitation setting) of the effect of occupational work evaluation on return to work in patients after myocardial infarction documented a 32-percent reduction in duration of convalescence (Dennis, Houston-Miller, Schwartz, et al., 1988).

## Stress and Psychological Well-Being

RECOMMENDATION: Education, counseling, and psychosocial interventions -- either alone or as components of multifactorial cardiac rehabilitation -- result in improved psychological well-being. Education, counseling, and behavioral interventions are recommended to complement the psychosocial benefits of exercise training.

### Scientific Evidence (Strength of Evidence = A)

Fourteen reports described the effects of education, counseling, and behavioral interventions as components of cardiac rehabilitation on psychological outcomes. Six were randomized controlled trials (Burgess, Lerner, D'Agostino, et al., 1987; Frasure-Smith and Prince, 1985; Friedman, Thoresen, Gill, et al., 1986; Gulanick, 1991; Oldridge, Guyatt, Jones, et al., 1991; Rahe, Ward, and Hayes, 1979). Six were nonrandomized controlled studies ( Adsett and Bruhn, 1968; Bohachick, 1984; Daumer and Miller, 1992; Langosch, Seer, Brodner, et al., 1982; Munro, Creamer, Haggerty, et al., 1988; Thoresen, Friedman, Powell, et al., 1985), and two were observational studies (Razin, Swencionis, and Zohman, 1986-87; Yates and Booton-Hiser, 1992). Details of the randomized and nonrandomized controlled trials are shown in Tables 11 and 12. In all 6 randomized controlled trials, beneficial results in several psychological outcomes favored intervention patients over control patients. These outcomes included improvements in scores of overwork behavior and time urgency Rahe, Ward, and Hayes, 1979), Type-A behavior (Friedman, Thoresen, Gill, et al., 1986), distress (Frasure-Smith and Prince, 1985), and quality-of-life and state anxiety measurements (at 8 weeks but not at 12 months) (Oldridge, Guyatt, Jones, et al., 1991). No differences between intervention and control groups were reported for depression (Burgess, Lerner, D'Agostino, et al., 1987; Oldridge, Guyatt, Jones, et al., 1991; Rahe, Ward, and Hayes, 1979), anxiety and life dissatisfaction Rahe, Ward, and Hayes, 1979), or self-efficacy (Gulanick, 1991).

Table 11. Effect of cardiac rehabilitation on stress and psychological well-being: Randomized controlled trials

Reference, Country | Patients | Intervention, Followup | | Outcome
Rahe, Ward, and Hayes (1979) United States | Sample size: 44 (22 group therapy, 22 control) Gender: 3 females group therapy, 1 control Age: Mean age group therapy 51 years, control 55 years Category: MI | Intervention: Every other week group therapy, 90 minutes/session, beginning 1 month after hospital discharge for 4 sessions. 1 session with patient and spouse, all other sessions spouse only. Main approach was education and discussion of coronary risk behaviors and their modification. Followup: 3-4 years | | Depression: Significant symptoms. No significant difference between groups. Levels of general anxiety: Not significantly different between groups Group therapy significantly decreased "over-work behavior," compared with controls (p < .03) Time urgency scores: Decreased in 62% group therapy vs. 25% control (p < .05) Life dissatisfaction scores: Not significantly different between groups
Friedman, Thoresen, Gill, et al. (1986) United States | Sample size: 946 (270 cardiac counseling, 592 cardiac counseling + Type-A behavioral counseling) Gender: 92% men Age: 64 years or younger, mean 53 years Category: At least 6 months following MI. Nonsmokers and nondiabetics. | Intervention: Type-A behavioral counseling with progressive muscle relaxation, behavioral learning, and cognitive affective learning. Control group cardiac counseling for 24 sessions, 90 minutes/session for 3 years for information on diet, exercise, and medication. 1 session every 3 months with psychiatrist or psychologist for general information. Followup: 3 years | | Type-A behavior: Reduced in 44% combined strategy group vs. 25% in cardiac counseling group (p < .001) Video-structured intervention scores: Significant reduction in combined strategy vs. cardiac counseling only (p < .01)
Frasure-Smith and Prince (1985) Canada | Sample size: 453 (229 intervention, 224 control) Gender: All men Age: 28-86 years, mean 58 years Category: MI | Intervention: Monthly telephone calls by project nurse for monitoring, using Goldberg's General Health Questionnaire to assess life stress. Score of 5 of 20 or less resulted in home visits by project nurse for lowering stress levels and other appropriate interventions. Followup: 1 year | | Intervention group significantly lower Goldberg's General Health Questionnaire scores suggesting less distress (p < .05)
Burgess, Lerner, D'Agostino, et al. (1987) United States | Sample size: 180 (89 intervention, 91 usual care) Gender: 85% men Age: 18-62 years, mean 51 years Category: MI (patients employed prior to MI) | Intervention: Enrolled last week of hospitalization, continued 3 months after discharge. Nurse or clinician-directed cognitive behavioral intervention mainly in patient's home, with average of 6.32 contacts per patient. Followup: 3 and 13 months | | Mean distress scores: Intervention group significantly lower vs. control (p < .04) Intense family support: Intervention group significantly less vs. control (p < .05) Measures of depression: No significant difference between groups 1-year distress and social support scores: No significant differences between groups
Oldridge, Guyatt, Jones, et al. (1991) Canada | Sample size: 201 total (exercise + behavioral counseling vs. control) Gender: 88% men Age: Mean 53 years Category: MI. Baseline moderate anxiety or depression, assessed 6 weeks following MI. | Intervention: Exercise training + behavioral group intervention by "group leaders (without formal training)." Eight 90-minute sessions of exercise, spouse included. Followup: 8 weeks and 12 months | | Quality of life emotions: Only significant difference at 8 weeks, with greater improvement intervention vs. control (p < .05) All other quality-of-life measures: No significant difference between groups State-anxiety: Decreased significantly intervention vs. control at 8 weeks (p < .05) Measures of depression: No significant difference between groups
Gulanick (1991) United States | Sample size: 40 (11 exercise testing, teaching, training; 15 no exercise training; 14 control) Gender: Not specified Age: 80 years and younger Category: 4 weeks following MI, CABG, or PTCA | Intervention: Supervised exercise training, details not specified. Education, 2 sessions of general information supplemented by 15-minute videotape describing recovery. Followup: 4-6 weeks | | All groups showed increase in self-efficacy scores for physical performance, with no significant difference between groups

Note: CABG = coronary artery bypass graft surgery; MI = myocardial infarction; PTCA = percutaneous transluminal coronary angioplasty.

Table 12. Effect of cardiac rehabilitation on stress and psychological well-being: Nonrandomized controlled trials

Reference, Country | Patients | Intervention, Followup | | Outcome
Adsett and Bruhn (1968) Canada | Sample size: 6 spouse pairs Gender: All men with spouses Age: Mean 49 years Category: MI | Intervention: Psychological counseling; 10 sessions in 6 months, 75 minutes/session. Group therapy to enhance coping and improve psychological response to MI. Followup: 6 months | | Patients and wives improved psychosocial adaptation; but small sample size. No statistically significant outcomes provided.
Langosch, Seer, Brodner, et al. (1982) Germany | Sample size: 90 (32 stress management, 28 relaxation training, 30 control) Gender: All men Age: Mean 48, 49, 50 years, respectively Category: MI | Intervention: Eight 1-hour sessions for 2 weeks. Stress management emphasized recognition and behavioral techniques to modify "pronounced achievement behavior." Jacobsonian muscular relaxation. Followup: 6 months | | Groups not significantly different at baseline Hypochondriasis and emotional lability: More improvement in both intervention groups vs. control. Emotional reactivity, depressed mood, assertiveness, or job involvement: No change in scores
Bohachick (1984) United States | Sample size: 37 (18 relaxation training, 19 control) Gender: Not specified Age: Not specified Category: Patients enrolled in cardiac exercise program | Intervention: Treatment group: 3 weeks of progressive relaxation training. Control: No training. Followup: 3 weeks | | State-anxiety scores significantly lower intervention group (p < .05) Symptom checklist-90, revised for symptom dimension somatization, interpersonal sensitivity, and anxiety/depression scores: Intervention group significantly lower (p < .05 vs. control group) Obsessive/compulsive or hostility dimension: No change in scores
Munro, Creamer, Haggerty, et al. (1988) United States | Sample size: 57 (27 intervention group, 30 control) Gender: All men Age: 35-54 years, mean 52 years Category: 2 weeks-10 years following MI | Intervention: Benson's relaxation technique taught first week exercise class + written instructions + cassette tapes. Practiced 1 or 2 times/day for 12 weeks. Followup: 12 weeks | | Sickness Impact Profile scores: Decreased significantly over time both groups (p < .001) No significant difference between groups
Daumer and Miller (1992) United States | Sample size: 47 (21 intervention, 26 control) Gender: 34 men, 13 women Age: 36-70 years, mean 58 years Category: CHD patients enrolled 6-8 weeks following acute events | Intervention: Weekly supervised treadmill or bike exercise, health education, and counseling. Home rehabilitation "physician-directed plan." Followup: 6-8 weeks after discharge | | Psychosocial measures: Not significantly different at baseline Quality-of-Life Index: No significant difference between groups Strong association between perceived life satisfaction and level of psychosocial functioning both groups
Thoresen, Friedman, Powell, et al. (1985) United States | Sample size: 862 combined routine cardiac and Type-A behavior counseling or routine cardiac counseling (controls). A nonrandomized nontreatment comparison group of 150 nonvolunteers. Gender: 92% men Age: Mean 53 years Category: MI | Intervention: Combined counseling patients seen in groups of 10 weekly for 2 months, semi-monthly for 4 months and monthly thereafter. Control patients seen in groups of 12 for 90 minute sessions biweekly for first 3 months, monthly for next 3 months, and bimonthly for remainder of study. Followup: 3 years | | Type-A behavior pattern scores: Mean decrease Type-A group 2.7 to 2.1 (p < .001) and 2.7 to 2.4 in cardiac counseling group (p < .05), p < .001 between groups Videotape-structured interview scores: Decreased significantly Type-A group (p < .001) Recurrent MI rate 181 patients with high degree Type-A: Improvement 1.7% vs. 8.6% in patients with less significant decrease in Type-A in Type-A (p < .001)

Note: CHD = coronary heart disease; MI = infarction.

Five of the six nonrandomized controlled trials reported statistically significant improvements in psychological outcomes (Adsett and Bruhn, 1968; Bohachick, 1984; Langosch, Seer, Brodner, et al., 1982; Munro, Creamer, Haggerty, et al., 1988; Thoresen, Friedman, Powell, et al., 1985), and one did not Daumer and Miller, 1992). Improvement in psychosocial outcomes favoring intervention patients over control patients occurred in hypochondriasis and emotional lability in relaxation and stress management groups Langosch, Seer, Brodner, et al., 1982); improved measures of state anxiety, somatization, interpersonal sensitivity, anxiety-depression, and Type-A behavior were also reported Bohachick, 1984; Thoresen, Friedman, Powell, et al., 1985). No differences between groups were reported for measures of emotional reactivity, depressed mood, assertiveness, and job involvement Langosch, Seer, Brodner, et al., 1982); scores of obsessive compulsiveness and hostility Bohachick, 1984; Thoresen, Friedman, Powell, et al., 1985); Sickness Impact Profile scores (Munro, Creamer, Haggerty, et al., 1988); and other measures of quality of life Daumer and Miller, 1992). One observational report of weekly group therapy for stress management that used relaxation techniques and management of anger reported improvement in mean global Type-A behavior scores as well as reductions in hostility, anger, depression, anxiety, obsessive-compulsive symptoms, interpersonal sensitivity, and somatization Razin, Swencionis, and Zohman, 1986-87).

### Conclusions

The studies cited provide evidence of psychological improvement following education, counseling, and/or psychosocial interventions. Training in behavior modification, stress management, and relaxation techniques is effective in lowering levels of self-reported emotional stress and in modifying Type-A behavior Friedman, Thoresen, Gill, et al., 1986; Thoresen, Friedman, Powell, et al., 1985). In the largest randomized controlled trial -- the Recurrent Coronary Prevention Project -- Type-A behaviors were modified in men and women in a nonrehabilitation setting Friedman, Thoresen, Gill, et al., 1986). Education, counseling, and psychosocial interventions in nonrehabilitation settings have been shown to improve time urgency and overwork behaviors (Rahe, Ward, and Hayes, 1979), reduce stress ( Frasure-Smith and Prince, 1985; Frasure-Smith and Prince, 1989), and improve measures of quality of life and anxiety (Oldridge, Guyatt, Jones, et al., 1991). Specific aspects of the psychological interventions responsible the beneficial psychological outcomes were not always provided. Interventions varied in duration and frequency and were delivered by personnel with varying expertise. Nonuniform outcome measures were used, making it difficult to compare results across studies. The better designed studies, which used more highly skilled or trained providers, demonstrated greater benefit.

## Morbidity

RECOMMENDATION: Education, counseling, and behavioral interventions are recommended as part of multifactorial risk intervention for patients with CHD to decrease progression of coronary atherosclerosis and lower coronary event rates. Cardiac rehabilitation education as a sole intervention appears ineffective in altering morbidity.

### Scientific Evidence (Strength of Evidence = B)

The scientific evidence of the effect of education, counseling, and behavioral interventions on morbidity outcomes included three randomized controlled studies, one of which showed benefit. In one randomized controlled trial of 461 male patients after myocardial infarction, intervention included monthly telephone contact from the project nurse, which was supplemented by home visits if measures of stress increased (Frasure-Smith and Prince, 1985). At 4 months to 1 year of followup, rehospitalizations for cardiac causes, rehospitalizations for all causes, and days of rehospitalization were not significantly different between intervention and control groups. In the second randomized controlled trial, patients after CABG received telephone followup by cardiac rehabilitation nurse specialists; these contacts were designed to enhance knowledge, improve decisionmaking, and improve coping and anxiety-reduction skills (Beckie, 1989). At the 6-week followup, significantly fewer intervention than control patients required rehospitalization. The third randomized controlled trial involved patients after myocardial infarction ( Heller, Knapp, Valenti, et al., 1993). Educational materials about diet, exercise, and smoking cessation were mailed to intervention patients during an 8-week period. These materials were supplemented by telephone calls. At the 6-month followup, there was no significant difference between intervention patients and usual-care patients in their need for cardiac catheterization, PTCA, CABG, or hospital readmission. This study used an educational approach without specific counseling or behavioral interventions.

### Conclusions

Based on the scientific evidence, education as a sole intervention may have limited beneficial effect on coronary event rates. Education, counseling, and behavioral interventions that are designed to encourage patients to adhere to therapies, including careful followup, may reduce coronary events. Intensive education, counseling, and behavioral interventions as components of multifactorial cardiac rehabilitation have been associated with reduction in recurrent coronary event rates as well as regression of atherosclerosis (Haskell, Alderman, Fair, et al., 1994).

## Mortality

RECOMMENDATION: Education, counseling, and behavioral interventions reduce cardiac and overall mortality rates and are recommended in the multifactorial rehabilitation management of patients with CHD.

### Scientific Evidence (Strength of Evidence = B)

Eight reports described the effects of education, counseling, and behavioral interventions on reduction in mortality rates Frasure-Smith and Prince, 1985; Frasure-Smith and Prince, 1989; Friedman, Thoresen, Gill, et al., 1986; Haskell, Alderman, Fair, et al., 1994; Ibrahim, Feldman, Sultz, et al., 1974; Karvetti and Hamalainen, 1993; Rahe, Ward, and Hayes, 1979; van Dixhoorn, Duivenvoorden, Staal, et al., 1987). Table 13 displays the eight randomized controlled trials, which were derived from seven study populations. Three randomized controlled trials did not show a statistically significant difference in mortality rates Ibrahim, Feldman, Sultz, et al., 1974; Rahe, Ward, and Hayes, 1979; van Dixhoorn, Duivenvoorden, Staal, et al., 1987). Three well-designed randomized controlled trials, presented in four reports Frasure-Smith and Prince, 1985; Frasure-Smith and Prince, 1989; Friedman, Thoresen, Gill, et al., 1986; Karvetti and Hamalainen, 1993), showed statistically significant reductions in mortality rates as benefit of cardiac rehabilitation education, counseling, and behavioral interventions. The magnitude of the benefit ranged from 4.5 to 12.2 percent. A randomized controlled trial involving patients following myocardial infarction that compared Type-A counseling with cardiac counseling documented a survival benefit favoring Type-A counseling (p < .01) Friedman, Thoresen, Gill, et al., 1986). A randomized controlled trial of patients after myocardial infarction compared exercise training plus relaxation training with exercise training only; at the 2- to 3-year followup, the mortality rates were 0 in the exercise-plus-relaxation training group compared with 4.3 percent in the exercise-only group; the sample size was insufficient to test whether the differences in mortality rates were statistically significant (van Dixhoorn, Duivenvoorden, Staal, et al., 1987). Another randomized controlled trial of male patients after myocardial infarction involved home nurse visits to reduce stress and provide counseling; this study demonstrated a significant reduction in 1-year cardiac death rate of 8.9 percent in the control group compared with 4.4 percent in the intervention group (p = .05) Frasure-Smith and Prince, 1985). At the 5-year followup, the death rates did not differ significantly Frasure-Smith and Prince, 1989). The final randomized controlled trial of male patients after myocardial infarction compared patients who received multifactorial cardiac rehabilitation (including smoking cessation, nutritional education, and behavioral counseling) with control patients Karvetti and Hamalainen, 1993). At the 3-year followup, total mortality was 19 percent in the intervention group compared with 31.2 percent in the control group, a statistically significant decrease of 12.2 percent.

Table 13. Effect of cardiac rehabilitation on mortality: Randomized controlled trials

Reference, Country | Patients | Intervention, Followup | | Outcome
Ibrahim, Feldman, Sultz, et al. (1974) United States | Sample size: 128 (68 intervention, 60 control) Gender: 11 women intervention, 10 women control Age: Not specified Category: MI | Intervention: Weekly group therapy, 90 minutes for 50 weeks led by clinical psychologists serving as catalysts for exploring emotions and attitudes regarding patient's physical and social conditions. Therapists were "nonmedical." Followup: 1 year | | 1-year survival rate: 10% increase intervention vs. control No statistically significant difference 1-year survival in severely ill patients: 93% intervention 74% control (p = .07)
Rahe, Ward, and Hayes (1979) United States | Sample size: 44 (22 group therapy, 22 control) Gender: 3 women group therapy, 1 control Age: Mean age 51 years group therapy, 55 years control Category: MI | Intervention: Every other week group therapy, 90 minutes/session, beginning 1 month after hospital discharge for 4 sessions. 1 session with patient and spouse, all other sessions spouse only. Main approach: Education and discussion about coronary risk behaviors and their modification. Followup: 3-4 years | | Cumulative mortality: Group therapy vs. control No significant difference at 4 years
Friedman, Thoresen, Gill, et al. (1986) United States | Sample size: 946 (270 cardiac counseling, 592 cardiac counseling + Type-A behavior counseling) Gender: Not specified Age: 64 years or younger, mean 53 years Category: At least 6 months following MI | Intervention: Cardiac counseling for 22 sessions, 90 minutes/session for 3 years for information on diet/exercise/medications. 1 session every 3 months with psychiatrist or psychologist for general information. Type-A behavioral counseling group also instructed in progressive muscle relaxation, behavioral learning, and cognitive affect learning. Followup: 3 years | | 3-year survival without recurrence of cardiac event: 94% in Type-A counseling group; 87% in cardiac counseling group (p < .01)
Frasure-Smith and Prince (1985) Canada (see also Frasure-Smith and Prince, 1989) | Sample size: 453 (229 intervention, 224 control) Gender: All male Age: 28-86 years, mean 58 years Category: MI | Intervention: Monthly telephone call by project nurse using Goldberg's General Health Questionnaire to assess life stress. Score of 5 of 20 or greater resulted in home visit by project nurse to lower stress levels and other appropriate interventions. Followup: 4 months-1 year | | Cardiac mortality: 4.4% intervention 8.9% control (p < .05) Difference in death rates noticeable 4-12 months following hospital discharge
van Dixhoorn, Duivenvoorden, Stall, et al. (1987) The Netherlands | Sample size: 90 (43 exercise training + relaxation, 47 exercise only. No nonexercise control group) Gender: 93% men Age: Not specified Category: MI | Intervention: Exercise interval training 0.5 hour once daily. Intensity 70-80% of maximal exercise test heart rate. Relaxation training group additional 1 time/week, six 1-hour sessions involving relaxation training using breathing techniques. Followup: 2-3 years | | Mortality: 0% (n = 43, 0 deaths) exercise/relaxation group; 4.3% (n = 47, 2 deaths) exercise-only group; "Group sizes too small to test for statistical significance"
Frasure-Smith and Prince (1989) United States (see also Frasure-Smith and Prince, 1985) | Sample size: 453 (229 intervention, 224 control) Gender: All men Age: 28-86 years, mean 58 years Category: MI | Intervention: 1-hour nurse visits in response to abnormal scores in Goldberg's General Health Questionnaire. Average, five 1-hour nurse visits supplemented by 6-7 brief telephone calls to patient by project nurse. Followup: 1, 2, 5, and up to 8.3 years | | 1-year cardiac mortality: 4.4% intervention; 8.9% control (p = .051) Statistically significant difference in outpatient cardiac mortality favoring intervention group. Difference did not persist beyond first year.
Karvetti and Hamalainen (1993) Finland | Sample size: 258 Gender: 199 men Age: 65 years and younger Category: 3-4 weeks after MI | Intervention: Multifactorial. Included antismoking and psychological counseling. Nutrition education, classes and individual, decreased fat calories < 30%, decreased dietary sugar, salt, and cholesterol; increase in low-fat foods. Weight reduction when appropriate. Nutrition instruction by nutritionist and dietitian. Intensive intervention first 3 months with continued intervention first 3 years. Followup: 1, 2, 6, and 10 years | | Total 3-year mortality: 19% intervention; 31.2% control (p = .05) 10-year mortality: Comparisons not provided
Haskell, Alderman, Fair, et al. (1994) United States | Sample size: 300 (72 of 145 medically treated usual care, 74 of 139 PTCA usual care, 10 of 16 CABG usual care vs. multifactorial individualized home rehabilitation) Gender: 83% men intervention, 92% men usual care Age: < 75 years, mean 57 years Category: Catheterization-documented stable CHD | Intervention: Multifactorial + lipid- lowering medications. Individual therapy guided by nurse manager including diet, behavioral management for smoking cessation, and lipid-lowering medication. Individual home exercise training with transtelephonic ECG monitoring. Followup: 4 years | | Total cardiac events including fatal MI, nonfatal MI, subsequent PTCA or CABG: 25 intervention; 44 usual care (p = .05) Cardiac or sudden unexplained death: 2 intervention; 3 usual care; no significant difference between groups

Note: CABG = coronary artery bypass graft surgery; ECG = electrocardiographic; MI = myocardial infarction; PTCA = percutaneous transluminal coronary angioplasty.

### Conclusions

A variety of education, counseling, and behavioral interventions are associated with reductions in total and cardiac mortality rates. The panel noted the consistency with which decreased mortality rates were reported in the randomized controlled trials of multifactorial cardiac rehabilitation involving education, counseling, and behavioral interventions. The five randomized controlled trials that reported favorable mortality outcomes all involved patients following myocardial infarction, principally men under 65 years of age, which limits the generalizability of the findings. The panel recognizes the potential for reducing mortality rates by education, counseling, and behavioral interventions that are designed to reduce cardiac risk as components of multifactorial cardiac rehabilitation.