# Effects of Cardiac Rehabilitation Exercise Training

This chapter discusses the effects of exercise training on exercise tolerance; strength training; exercise habits; symptoms; cardiovascular risk factors including smoking, lipids, body weight, and blood pressure; psychological well-being; social adjustment and functioning; return to work; morbidity and safety; mortality and safety; pathophysiologic measures; patients with heart failure and cardiac transplantation; and elderly patients.

## Exercise Tolerance

RECOMMENDATION: Cardiac rehabilitation exercise training consistently improves objective measures of exercise tolerance, without significant cardiovascular complications or other adverse outcomes. Appropriately prescribed and conducted exercise training is recommended as an integral component of cardiac rehabilitation services, particularly for patients with decreased exercise tolerance. Continued exercise training is required to sustain improved exercise tolerance.

### Scientific Evidence (Strength of Evidence = A)

One hundred fourteen scientific reports addressed the effect of cardiac rehabilitation exercise training on measures of exercise tolerance. Of these, 46 were reports of randomized controlled trials, 25 of nonrandomized controlled trials, and 43 of observational studies.

#### Randomized Controlled Trials

Thirty-five of the 46 randomized controlled trials compared cardiac rehabilitation exercise training (with and without other rehabilitation services) with a no-exercise control group. The 11 remaining randomized controlled trials evaluated other issues pertaining to exercise training such as comparison of various intensities of exercise training or exercise training as a sole intervention compared with multifactorial cardiac rehabilitation. Of the 35 exercise-training versus no-exercise randomized controlled trials, 13 of the 14 U.S. studies reported statistically significant improvement in exercise tolerance in exercise versus control patient groups (DeBusk, Haskell, Miller, et al., 1985; DeBusk, Houston, Haskell, et al., 1979; DeBusk, Houston Miller, Superko, et al., 1994; Fletcher, Dunbar, Felner, et al., 1994; Foster, Pollock, Anholm, et al., 1984; Froelicher, Jensen, Genter, et al., 1984; Haskell, Alderman, Fair, et al., 1994; Hung, Gordon, Houston, et al., 1984; May and Nagle, 1984; Ornish, Scherwitz, Doody, et al., 1983; Sebrechts, Klein, Ahnve, et al., 1986; Stern, Gorman, and Kaslow, 1983; Taylor, Houston-Miller, Ahn, et al., 1986). One U.S. trial reported no significant difference between exercise and control subjects (Sivarajan, Bruce, Lindskog, et al., 1982). Statistically significant improvement in exercise tolerance also was reported in 17 of the 21 non-U.S. trials (Bengtsson, 1983; Carson, Phillips, Lloyd, et al., 1982; Coats, Adamopoulos, Meyer, et al., 1990; Engblom, Hietanen, Hamalainen, et al., 1992; Giannuzzi, Tavazzi, Temporelli, et al., 1993; Giannuzzi, Temporelli, Tavazzi, et al., 1992; Grodzinski, Jette, Blumchen, et al., 1987; Hambrecht, Niebauer, Marburger, et al., 1993; Marra, Paolillo, Spadaccini, et al., 1985; Mayou, MacMahon, Sleight, et al., 1981; Meyer, Casadei, Coats, et al., 1991; Newton, Mutrie, and McCarthur, 1991; Nolewajka, Kostuk, Rechnitzer, et al., 1979; Oldridge, Guyatt, Jones, et al., 1991; Oldridge, McCartney, Hicks, et 1989; Schuler, Hambrecht, Schlierf, et al., 1992b; Wilhelmsen, Sanne, Elmfeldt, et al., 1975). One additional non-U.S. trial that reported significant improvement in exercise tolerance did not provide measures of statistical significance ( Roman, Gutierrez, Luksic, et al., 1983). U.S. and non-U.S. trials are described separately because of the differences in medical and social systems. Thus, 30 of 35 randomized controlled trials that compared exercise training versus no exercise documented a statistically significant improvement in exercise tolerance in intervention versus control patients. These randomized controlled trials are summarized in Tables 1 and 2. The proportion of randomized controlled trials that documented benefit for intervention versus control patients is displayed in Figure 2, which compares (a) U.S. and non-U.S. studies, (b) multifactorial versus exercise-only studies, (c) studies that specified exercise intensity versus those that did not, and (d) studies that used various durations of exercise training.s As shown in Figure 2, 12 of the 16 multifactorial rehabilitation trials documented a statistically significant increase in exercise tolerance in the intervention compared with control groups, as did 18 of the 19 exercise-only trials. Twenty-five of the 26 randomized controlled trials that specified exercise intensity, using 60-90 percent of the peak heart rate at baseline exercise testing, demonstrated benefit for the intervention patients. Five of the nine randomized controlled trials that did not specify exercise intensity failed to demonstrate benefit in exercise tolerance in intervention versus control patients. Thus, five of the six studies that showed no difference between intervention and control patients did not specify exercise intensity in the study methodology. As shown in Figure 2, 10 of the 12 trials that involved 8-12 weeks of exercise training, as well as 16 of the 18 longer duration exercise-training studies, reported a statistically significant increase in exercise tolerance favoring intervention versus control patients. None of the 35 randomized controlled trials that compared exercise training with a no-exercise control group reported a statistically significant greater improvement in exercise tolerance in the control versus the intervention group.

Figure 1. Decision tree for cardiac rehabilitation services --Assessment and Individualization of Treatment Plan

Figure 2. Proportion of randomized controlled trials of the effects of exercise training reporting significantly greater improvement in exercise tolerance in intervention vs. control groups, by selected characteristics

Table 1. Exercise tolerance outcomes of cardiac rehabilitation: U.S. randomized controlled trials of exercise training

Reference | Patients | Setting, Intervention, Followup | | Outcome
DeBusk, Houston, Haskell, et al. (1979) | Sample size: 70 (28 supervised gymnasium exercise training, 12 home exercise training, 30 no training controls) Gender: 100% men Age: Mean 54 years Category: Uncomplicated MI | Setting: Home and center Intervention: Supervised gymnasium aerobic exercise for 1 hour, 3 times/week for 8 weeks at 70-80% maximal baseline exercise test heart rate. Home exercise for 30 minutes, 7 days/week, cycle ergometry, at 70-80% maximal baseline exercise test heart rate. Followup: 11 weeks | | Percentage increase functional capacity: gymnasium exercise 53%, home exercise 41%, controls 34% (p < .01 both exercise groups vs. control), but not significant between exercise groups
Sivarajan, Bruce, Lindskog, et al. (1982) | Sample size: 258 (88 exercise-only, 86 exercise + teaching/counseling, 84 control) Gender: 80% men Age: 70 years and younger, mean 56-57 years Category: Uncomplicated MI | Setting: Home and rehabilitation center Intervention: Home exercise prescribed, modified or upgraded at weekly clinic visits. Exercise twice/day until return to work, then once daily. Intensity individually prescribed. 3 month duration both groups + education/counseling, eight 1-hour group sessions weekly. Followup: 3, 6 months | | No differences among groups in the hemodynamic response to low-level exercise testing at 3 or 6 months
Ornish, Scherwitz, Doody, et al. (1983) | Sample size: 46 (27 intervention, 19 control) Gender: Not specified Age: Not specified Category: Stable catheterization-documented CHD | Setting: Residential Intervention: 14-day program, 5 hours daily stress management, vegetarian diet, 3 hours/week exercise, twice/week social support meeting Followup: 24 days | | Significant increase in exercise tolerance, intervention vs. control (p < .001). Total work performance increased intervention and decreased control (p < .0001 between groups).
Stern, Gorman, and Kaslow (1983) | Sample size: 91 (31 group counseling, 38 exercise training, 22 control) Gender: 86% men Age: Mean 54 years, 30-69 years Category: MI | Setting: Outpatient rehabilitation center Intervention: Supervised exercise 3 times/week for 12 weeks at 85% maximal baseline exercise test heart rate. Group counseling once/week for 12 weeks, 60-75 minutes. Followup: 3, 6, and 12 months | | Significant increase exercise tolerance exercise group only compared with other 2 groups at 3 and 6 months (p < .001). No difference at 12 months.
Froelicher, Jensen, Genter, et al. (1984) | Sample size: 146 (72 intervention, 74 control) Gender: 100% men Age: Mean 53 years, 35-65 years Category: Stable CHD patients | Setting: Hospital outpatient rehabilitation center Intervention: Supervised aerobic exercise 45 minutes 3 times/week at 60-85% estimated maximal oxygen consumption at baseline exercise test for initial 8 weeks. Followed by 46 weeks gymnasium or walk/run program. Followup: 1 year | | Significant increase in submaximal and maximal exercise tolerance, intervention vs. control (p < .05) Oxygen consumption increased significantly and rest and submaximal heart rate decreased significantly in exercise vs. control patients (p < .05).
Hung, Gordon, Houston, et al. (1984) | Sample size: 53 (23 intervention, 30 control) Gender: 100% men Age: 70 and younger, mean 55 years Category: Uncomplicated MI | Setting: Home Intervention: Cycle ergometry exercise with transtelephonic ECG monitoring. 30-minute sessions 5 times/week for 11 weeks at 70-85% maximal baseline exercise test heart rate. Followup: 26 weeks | | Significant increase in exercise tolerance, intervention vs. control (p < .01)
May and Nagle (1984) | Sample size: 121 (71 exercise coronary, 50 coronary controls, 24 controls without known coronary disease) Gender: Not specified Age: Mean 50 years Category: Stable catheterization-documented CHD | Setting: Outpatient rehabilitation program Intervention: Supervised aerobic exercise 2-3 times/week for 50-75 minutes/session at 70-80% maximal baseline exercise test heart rate for 10-12 months Followup: 10-12 months | | Significant increase in maximal oxygen consumption intervention group only vs. control (p < .01) Significant decrease submaximal rate-pressure product, significant increase maximal rate-pressure product, intervention vs. control (p < .01)
Foster, Pollock, Anholm, et al. (1984) | Sample size: 28 (19 intervention, 9 control) Gender: Not specified Age: Mean 56 years for intervention group, 58 years control group Category: CABG | Setting: Hospital outpatient rehabilitation center Intervention: Treadmill and cycle ergometry for 50-60 minutes at 50-70% heart rate reserve for 24 weeks, frequency not specified Followup: 24 weeks following CABG | | Significant increase in work capacity intervention vs. control (p < .05).
DeBusk, Haskell, Miller, et al. (1985) | Sample size: 100 (30 gymnasium exercise, 33 transtelephonic ECG monitored home exercise, 37 no-exercise controls) Gender: 100% men Age: Mean 53 years Category: Uncomplicated MI | Setting: Supervised gymnasium and home Intervention: Exercise training both groups at 70-85% maximal baseline exercise test heart rate, 5 times/week for 30 minutes Followup: 26 weeks | | Significantly greater increase in exercise tolerance both exercise groups vs. control (p < .05). No significant difference between gymnasium and home exercise groups.
Taylor, Houston- Miller, Ahn, et al. (1986) | Sample size: 143 (24 exercise test only, 48 exercise test and home exercise, 45 exercise test and supervised gymnasium exercise, 26 no exercise test and no training) Gender: 100% men Age: 70 years and younger Category: Within 3 weeks of uncomplicated MI | Setting: Home and gymnasium Intervention: Exercise training similar intensity. Frequency and duration, specifics not provided Followup: 26 weeks | | Increase in functional capacity significantly greater in exercise vs. no-exercise groups (p < .05). No significant difference between home and gymnasium exercise groups.
Sebrechts, Klein, Ahnve, et al. (1986) | Sample size: 56 (27 intervention, 29 control) Gender: 100% men Age: Mean 53 years intervention, 55 years controls Category: Stable CHD (77% prior MI); heart failure, claudication, CABG excluded | Setting: Rehabilitation center Intervention: Supervised aerobic exercise 1 hour, 3 times/week at 75-80% maximal oxygen uptake at baseline; 1 year duration Followup: 1 year | | Significant increase in maximal estimated oxygen consumption (p < .001) and exercise duration (p < .01) intervention group only
Haskell, Alderman, Fair, et al. (1994) | Sample size: 300 (72 of 145 medically treated patients usual care; 74 of 139 PTCA patients usual care; 10 of 16 CABG surgery patients usual care vs. multifactorial individualized home rehabilitation) Gender: 83% men intervention, 92% men usual care Age: < 75 years, mean 57 years Category: Catheterization-documented stable CHD; no heart failure | Setting: Home rehabilitation Intervention: Multifactorial + lipid-lowering medications. Individual therapy guided by nurse manager including diet, behavioral management for smoking cessation, lipid-lowering medication + individual home exercise training with transtelephonic ECG monitoring. Followup: 4 years | | Increased exercise tolerance intervention vs. usual care (p = .001 between groups)
DeBusk, Houston Miller, Superko, et al. (1994) | Sample size: 585 (293 intervention, 292 usual care); 77% Caucasian, 62% college-educated or more Gender: 79% men Age: < 70 years, mean 57 years Category: Clinically stable MI | Setting: Home rehabilitation Intervention: Multifactorial. Home exercise 60-85% maximal baseline exercise test heart rate 30 minutes 5 times/week for initial 4 weeks, 100% thereafter; diet and exercise education and counseling periodically; transtelephonic ECG and portable heart rate monitoring and self-monitoring logs. Followup: 6 months | | Significant increase in functional capacity special intervention vs. usual care (p < .001 between groups)
Fletcher, Dunbar, Felner, et al. (1994) | Sample size: 88 (41 intervention, 47 control) Gender: 100% men Age: 42-72 years, mean 62 years Category: Catheterization-documented stable CHD + physical disability allowing use of 1 arm for exercise testing and training | Setting: Home Intervention: Exercise training with transtelephonic ECG monitoring. Arm exercise specially adapted wheelchair cranking 20 minutes 5 times/week for 6 months + Step 1 diet (both groups). Exercise intensity not specified. Followup: 6 months | | Significant decrease in resting heart rate and mean peak rate pressure product vs. baseline intervention group only (p = .03) No significant difference between groups in exercise duration, maximal oxygen consumption or rating of perceived exertion

Note: CABG = coronary artery bypass graft surgery; CHD = coronary heart disease; ECG = electrocardiographic; MI = myocardial infarction; PTCA = percutaneous transluminal coronary angioplasty.

Table 2. Exercise tolerance outcomes of cardiac rehabilitation: Non-U.S. randomized controlled trials of exercise training

Reference | Patients | Setting, Intervention, Followup | | Outcome
Wilhelmsen, Sanne, Elmfeldt, et al. (1975) | Sample size: 315 (158 intervention, 157 control) Gender: 138 men intervention, 142 men control Age: < 57 years, mean 51 years Category: 3 months following MI | Setting: Sweden, hospital outpatient center Intervention: Supervised aerobic exercise 3.5 hours/week at 80% of baseline maximal exercise test heart rate + supplemental home cycle ergometry. 9-months duration. Followup: 1 year | | Significant decrease submaximal heart rate vs. baseline intervention patients only. No significant change at higher workloads
Plavsic, Turkulin, Perman, et al. (1976) | Sample size: 53 Gender: 100% men Age: < 60 years Category: MI | Setting: Yugoslavia, outpatient rehabilitation center Intervention: Diet, lifestyle, and drug treatment for all patients. Intervention patients, 45 minutes aerobic exercise 2 times/week (duration, intensity and mode not specified). Followup: 6-24 months | | No significant change in measures of exercise tolerance in either group
Nolewajka, Kostuk, Rechnitzer, et al. (1979) | Sample size: 20 (10 intervention, 10 control) Gender: 100% men Age: 36-54 years, mean 48 years Category: MI 3-6 months previously | Setting: Canada, rehabilitation center Intervention: Supervised aerobic exercise 4 times/week for 1 hour at 60-70% of maximal baseline exercise test heart rate + 1 day unsupervised home exercise. Control subjects 2 times/week nontraining gymnasium recreational activity. Followup: 7 months | | Exercise time to anginal threshold significantly increased in exercise group compared with baseline (p < .01). No change in control group. Differences between groups not specified
Kallio, Hamalainen, Hakkila, et al. (1979) | Sample size: 375 (187 intervention, 188 control) Gender: 150 men intervention, 151 men control Age: < 65 years, mean 54 years Category: 2 weeks following hospital discharge after MI | Setting: Finland, setting not specified Intervention: Supervised cycle ergometry exercise training. Intensity and frequency not specified. "Most intensive" first 3 months, + health education and psychosocial advice. Duration 3 years. Followup: 3 years | | Cycle ergometry physical work capacity at 1, 2, and 3 years, not significantly different intervention vs. control
Mayou, MacMahon, Sleight, et al. (1981) | Sample size: 115 (43 exercise, 35 advice only, 37 control) Gender: 100% men Age: 28-60 years, mean 57 years Category: Within 4 weeks following MI | Setting: England, outpatient rehabilitation Intervention: 8 aerobic exercise sessions, 2 times/week for 4 weeks. Intensity not specified. 3-4 advice sessions to couples by cardiac nurse. Followup: 3 months | | Significant improvement in submaximal exercise tolerance exercise vs. other 2 groups (p < .001)
Carson, Phillips, Lloyd, et al. (1982) | Sample size: 303 (151 intervention, 152 control) Gender: Not specified Age: < 70 years Category: Following MI. Heart failure and comorbid conditions excluded. | Setting: England, hospital gymnasium Intervention: Supervised aerobic exercise 2 times/week for 12 weeks. Intensity not specified. Isometric exercise proscribed. Followup: 3 years | | Functional capacity at exercise testing significantly higher intervention vs. control at 5 months, 1 year, and 2 years, but not at 3 years (p < .001)
Roman, Gutierrez, Luksic, et al. (1983) | Sample size: 193 (93 intervention, 100 control) Gender: 87 men intervention, 87 men control Age: Mean age 56 years intervention, 59 years control Category: Following MI. Infarct location, severity, and baseline risk factors well- matched. | Setting: Chile, outpatient rehabilitation center Intervention: Supervised aerobic exercise 30 minutes, 3 times/week at 70% maximal baseline exercise test heart rate for 42 months mean training duration Followup: 12 months | | Peak oxygen consumption significantly increased over baseline intervention patients at 6 months and nonsignificant further increase at 12 months (no p value provided). Control no increase. Difference between groups remained significant at 12 months.
Bengtsson (1983) | Sample size: 126 (62 intervention, 64 control) Gender: 80% men Age: 39-65 years Category: MI | Setting: Sweden, hospital outpatient rehabilitation Intervention: Multifactorial. Supervised aerobic exercise minutes 2 times/week for 3 months at 90% baseline exercise test heart rate + individual group and family counseling. Followup: 14 months | | Significantly lower systolic blood pressure, rest and submaximal exercise, intervention vs. control (p < .005) No significant difference between groups at maximal workload at 1 year
Marra, Paolillo, Spadaccini, et al. (1985) | Sample size: 161 (81 intervention, 80 control). High risk patients excluded. Gender: Not specified Age: 25-65 years, mean 49 years Category: 45 days following MI | Setting: Italy, outpatient rehabilitation center Intervention: Supervised monitored exercise 1 hour 4 times/week at 80-90% maximal baseline exercise test heart rate for 8-9 weeks. Control: Home exercise-cycling, walking, and calisthenics. Followup: 4.5 years | | Physical work capacity and maximal double product significantly greater supervised exercise vs. control home exercise (p < .001) 55 months after completion of exercise training
Grodzinski, Jette, Blumchen, et al. (1987) | Sample size: 99 (53 intervention, 46 control). 33 patients resting ejection fraction equal to or < 45% (20 intervention, 13 control). Gender: 93 men Age: 33-62 years, mean 48 years Category: 5-8 weeks following MI | Setting: Germany, outpatient rehabilitation center Intervention: Aerobic exercise twice/day, 5 times/week, 30 minutes/session, intensity 80% maximal baseline exercise test heart rate Followup: 5 weeks | | Significant increase in exercise tolerance intervention vs. control (p < .05) Equal improvement in patients with low baseline ejection fraction.
Oldridge, McCartney, Hicks, et al. (1989) | Sample size: 22 (12 intervention, 10 control). Gender: 100% men Age: < 65 years, mean 53 years Category: Stable catheterization documented CHD | Setting: Canada rehabilitation center and home Intervention: Progressive incremental cycle ergometer exercise: 75-90 minute duration, 65-80% baseline maximal exercise test functional capacity. 2 rehabilitation center sessions/week + 3 home (requested). Followup: 3 months | | 18% increase in peak oxygen consumption in exercise group (p < .005). Controls no change. 21% increase in maximal power output exercise vs. control (p < .005). Isokinetic peak power increased 14% and total work increased 1% in exercise group (both p < .001). Control group decreased 6% and 8%, respectively.
Hamalainen, Luurila, Kallio, et al. (1989) | Sample size: 375 (188 intervention, 187 control) Gender: 80% men Age: < 65 years Category: Consecutive patients following MI. Exercise began "a few weeks" following MI. | Setting: Finland, outpatient rehabilitation center Intervention: Multifactorial. Exercise "tailored to individual capacity" (details not specified) + antismoking and diet advice, psychosocial counseling. Duration specified. Followup: 10 years | | No significant difference at maximal cycle ergometry exercise testing between groups at 10 years.
Coats, Adamopoulos, Meyer, et al. (1990) | Sample size: 11 Gender: Not specified Age: Mean 63 years Category: Stable heart failure and diminished left ventricular systolic ejection fraction (mean 0.19) | Setting: England, home Intervention: Cycle exercise with pulse rate monitor intensity at 70-80% maximal baseline exercise test heart rate, 20 minutes/session, 5 times/week for 8 weeks. Rest crossover design. Followup: 16 weeks | | Significant increase (p < .05) in cycle exercise time, peak oxygen uptake at end of exercise phase. Significant decrease in submaximal rate-pressure product compared with nontraining period (p < .05)
Newton, Mutrie, and McCarthur (1991) | Sample size: 22 (12 intervention, 10 usual care) Gender: 73% men Age: < 70 years Category: MI | Setting: Scotland, outpatient rehabilitation center Intervention: Exercise-based rehabilitation. Intensity 60-80% maximal baseline exercise test heart rate. Details not specified. Followup: 10 weeks | | Significant increase exercise duration both groups vs. baseline (p < .01) No significant difference between groups.
Meyer, Casadei, Coats, et al. (1991) | Sample size: 15 Gender: 14 men Age: 45-75 years, mean 63 years Category: Decreased left ventricular systolic function (mean ejection fraction 0. 23). 12/15 ischemic cardiomyopathy. | Setting: England, home Intervention: Crossover study design. Cycle ergometry 5 days/week for 20-25 minutes at 70-80% baseline maximal exercise test heart rate for 6 weeks. Random crossover 6 weeks no training. In addition, 12 week blocks lisinopril, 10 mg/day vs. matching placebo 12 week block with exercise and nonexercise for 6 weeks each. Followup: 6 weeks | | Significant increase in submaximal exercise tolerance and decrease in submaximal rate-pressure product with lisinopril + exercise or lisinopril-only vs. baseline (p < .05) Peak exercise tolerance increased significantly with training with and without lisinopril vs. baseline or lisinopril only (p < .05).
Oldridge, Guyatt, Jones, et al. (1991) | Sample size: 201 (99 intervention, 102 usual care) Gender: 88% men Age: Not specified Category: MI | Setting: Canada, outpatient rehabilitation center Intervention: Multifactorial. Behavioral counseling patient and spouse + supervised aerobic exercise 50 minutes 2 times/week for 8 weeks at 65% maximal baseline exercise test heart rate. Followup: 12 months | | Significant increase in exercise tolerance intervention vs. control at 8 weeks (p < .05), but not at 12 months
Schuler, Hambrecht, Schlierf, et al. (1992b) | Sample size: 113 (56 intervention, 57 usual care) Gender: 100% men Age: Mean 53 years Category: Catheterization-documented stable CHD | Setting: Germany, outpatient rehabilitation center Intervention: Multifactorial. 2 hours/week exercise training 75-85% maximal baseline exercise test heart rate for 1 year + strict diet. Followup: 1 year | | Significant improvement in exercise tolerance (physical work capacity, maximal oxygen consumption), intervention vs. control (p > .05)
Giannuzzi, Temporelli, Tavazzi, et al. (1992) | Sample size: 49 (25 intervention, control). 14 patients baseline, left ventricular ejection fraction < 0.40. Gender: 100% men Age: Mean 51 years Category: 4-8 weeks following first anterior Q-wave MI | Setting: Italy, outpatient rehabilitation centers Intervention: Supervised cycle ergometry, 30 minutes, 3 times/week, 80% maximal baseline exercise test heart rate for 2 months. Next 4 months home exercise (details not specified). Followup: 6 months | | Physical work capacity increased significantly exercise vs. control (p < .03) Heart rate, rate-pressure product at same maximal workload decreased significantly exercise group only (p < .03)
Engblom, Hietanen, Hamalainen, et al. (1992) | Sample size: 171 (93 intervention, 78 control) Gender: 100% men Age: < 65 years, mean 54 years Category: 6-8 weeks postoperative CABG surgery | Setting: Finland, outpatient rehabilitation center Intervention: 21 hours supervised aerobic exercise for 3 weeks, 70% maximal baseline exercise test heart rate. Diet advice and group psychological therapy. Followup: 6 and 12 months | | Significant increase in physical work capacity rehabilitation vs. control groups at 6 and 12 months (p < .05)
Hambrecht, Niebauer, Marburger, et al. (1993) | Sample size: 88 (45 intervention, control) Gender: 100% men Age: Mean 54 years Category: Stable angina and catheterization documented CHD. Ejection fraction, < 35% excluded, mean ejection fraction, 57%. | Setting: Germany, hospital and home Intervention: Initial 3 week metabolic ward diet + cycle ergometry exercise 6 times/day for 10 minute sessions 75% baseline exercise test maximal oxygen consumption, followed by home exercise 30 minutes/day 75% intensity + 2 group training sessions 60 minutes/week. Diet and psych. Followup: 1 year | | Significant increase exercise tolerance (maximal oxygen consumption), intervention vs. control (p < .05) Significant increase maximal exercise duration, intervention vs. control (p < .001)
Giannuzzi, Tavazzi, Temporelli, et al. (1993) | Sample size: 103 (51 intervention, 52 control) Gender: 100% men Age: Mean 51 years Category: 4-6 weeks following 1st anterior Q-wave MI. Greater use of angiotensin-converting enzyme inhibitors, intervention vs. control patients (28 vs. 10%, p = .047). Left ventricular ejection fraction < 25% or baseline physical work capacity < 50 watts or angina at < 50 watts excluded. | Setting: Italy, outpatient rehabilitation centers, home Intervention: Supervised cycle ergometry, 30 minutes 3 times/week for 2 months, 80% maximal baseline exercise test heart rate followed by 4 months home exercise training 3 times/week at 80% intensity + 30 minutes daily walking Followup: 6 months | | Significant increase maximal work capacity and increased lactate anaerobic threshold intervention group only (p = .001 vs. baseline) At same maximal workload, significant reduction in heart rate, rate-pressure product and venous lactate concentration intervention vs. control (p < .01). Further deterioration echo left ventricular performance with ejection fraction < 40% at baseline without difference between groups.

Note: CABG = coronary artery bypass graft surgery; CHD = coronary heart disease; MI = myocardial infarction.

The effects of lower versus higher intensities of exercise training on exercise tolerance were evaluated in five randomized controlled trials (Blumenthal, Emery, and Rejeski, 1988; Blumenthal, Rejeski, Walsh-Riddle, et al., 1988; Goble, Hare, Macdonald, et al. 1991; Rechnitzer, Cunningham, Andrew, et al., 1983; Worcester, Hare, Oliver, et al., 1993). Two reports were from the same clinical center (Blumenthal, Emery, and Rejeski, 1988; Blumenthal, Rejeski, Walsh-Riddle, et al., 1988). The details of these studies are provided in Table 3. Three trials documented a significantly greater improvement in exercise tolerance comparing higher and lower intensity exercise prescription (Goble, Hare, Macdonald, et al., 1991; Rechnitzer, Cunningham, Andrew, et al., 1983; Worcester, Hare, Oliver, et al., 1993). In one of these studies, although exercise tolerance at 8 weeks was greater with high-intensity exercise, there was no significant difference between groups at the 1-year followup ( Goble, Hare, Macdonald, et al., 1991). The two reports from the same study population found no significant differences in exercise tolerance between lower and higher intensity exercise training (Blumenthal, Emery, and Rejeski, 1988; Blumenthal, Rejeski, Walsh-Riddle., et al., 1988).

Table 3. Exercise tolerance outcomes: Randomized controlled trials of higher versus lower intensity exercise training

Reference, Country | Patients | Intervention, Followup | | Outcome
Rechnitzer, Cunningham, Andrew, et al. (1983) Canada | Sample size: 390 high-intensity, 371 low-intensity Gender: 100% men Age: Median 47 years high-intensity, median 48 years low-intensity Category: MI | Intervention: High-intensity walking/jogging, 65-85% estimated maximal baseline oxygen uptake, supervised twice/week for 8 weeks + 4 times/week home exercise. once/week relaxation meeting and activity < 50% maximal baseline estimated oxygen uptake. Followup: 4 years | | Significant reduction in heart rate, high-intensity vs. low-intensity subjects (p = .01) at same submaximal workload
Blumenthal, Rejeski, Walsh-Riddle, et al. (1988) United States | Sample size: 70 Gender: 100% men Age: 27-67 years, median 54 years Category: 3-52 weeks following MI (mean 12 weeks) | Intervention: Moderate/high-intensity (60-75% MVO[sub]2) or low-intensity ( <45% MVO[sub]2) exercise training for 12 weeks. Supervised 10-minute warm-up, 35-minute aerobic stimulus, 10-minute cooldown 3 times/week for 12 weeks. Followup: 12 weeks | | Significant increase (mean 15%) in functional capacity both high- and low-intensity groups at 3 months vs. baseline (p < .01) No significant difference between groups
Blumenthal, Emery, and Rejeski (1988) United States | Sample size: 46 Gender: 100% men Age: Median 51.5 years Category: Average 8 weeks following MI | Intervention: Supervised aerobic exercise 3 times/week for 12 weeks. High-intensity (65-75% MVO[sub]2) or low-intensity (<45% MVO[sub]2) exercise Followup: 12 weeks | | Mean increase MVO[sub]2 high- intensity exercise 11% vs. 14% low-intensity exercise No significant difference between groups
Goble, Hare, Macdonald, et al. (1991) Australia | Sample size: 337 Gender: 100% men Age: 70 years and younger Category: MI | Intervention: 30-minute aerobic exercise training 70-85% maximal baseline heart rate 3 times/week for 8 weeks. Light exercise, limited activity in classes 2 times/week for 8 weeks. Both groups encouraged to walk daily at home. Followup: 8 weeks and 52 weeks | | Exercise training: 6.8 mean MET level at baseline increased to 10.8 at week 8 Light exercise: 6.7 mean MET level at baseline increased to 9.9 at week 8 (p = .002 between groups) 1 year mean MET level 10.8 exercise training vs. 10.7 light exercise. No significant difference between groups.
Worcester, Hare, Oliver, et al. (1993) Australia | Sample size: 224 (108 high-intensity exercise training, 116 low-intensity exercise training) Gender: 100% men Age: Mean 54 years Category: MI | Intervention: High-intensity exercise: 30-minute aerobic exercise at 70-85% maximal baseline heart rate 3 times/week for 8 weeks. Low-intensity exercise: Limited activity in classes 2 times/week for 8 weeks. Both groups encouraged to walk daily at home. Followup: 4 and 12 months | | 11-week followup exercise testing: mean MET in high- intensity exercise group significantly greater (10.7) compared with light-exercise group (9.7)(p = .005)

Note: MET = metabolic equivalent units; MI = myocardial infarction; MVO[sub]2 = maximal oxygen uptake

The frequency of exercise training in the 35 randomized controlled trials varied between two and seven times per week. The most common frequency was three times per week (19 studies), and the second most common was five times per week (8 studies). The weekly frequency of exercise did not relate to improvement in exercise tolerance. Of the five randomized controlled trials that did not demonstrate improvement in exercise tolerance with cardiac rehabilitation exercise training, one had an exercise frequency of two times per week (Plavsic, Turkulin, Perman, et al., 1976), one had a frequency of three times per week ( Roman, Gutierrez, Luksic, et al., 1983), and the remaining two trials that did not demonstrate benefit did not specify the frequency of exercise training (Hamalainen, Luurila, Kallio, et al., 1989; Kallio, Hamalainen, Hakkila, et al., 1979); one used daily home exercise in addition to group exercise once per week (Sivarajan, Bruce, Lindskog, et al., 1982).

Twenty of the 46 randomized controlled trials included a small proportion of women, between 6 and 28 percent. No trial reported exercise tolerance outcome by gender.

#### Nonrandomized Controlled Trials

Twenty-two of the 25 nonrandomized controlled trials reported statistically significant improvements in measures of submaximal exercise tolerance and/or maximal exercise tolerance following exercise training. The beneficial physiologic adaptations to exercise training included a reduction in anginal symptoms at exercise testing (Hedback, Perk, and Engvall, 1992; Hedback, Perk, Engvall, et al., 1990; Ribiero, Hartley, Sherwood, et al., 1984); decreases in heart rate, rate-pressure product, or both, at submaximal workloads ( Hands, Briffa, Henderson, et al., 1987; Naughton, Bruhn, and Lategola, 1968; Raineri, Assennato, Candela, et al., 1982); augmented physical work capacity, expressed as kilograms per minute (kg/min) or watts (Ben-Ari, Kellermann, Fisman, et al., 1986; Cardus, McTaggart, and Ribas-Cardus, 1980; Hedback and Perk, 1987; Hoffmann, Duba, Lengyel, et al., 1987; Jugdutt, Michorowski, and Kappagoda, 1988; Raineri, Assennato, Candela, et al., 1982; Ribiero, Hartley, Sherwood, et al., 1984; Schuler, Hambrecht, Schlierf, et al., 1992b); increased measured or estimated aerobic capacity (VO[sub2]max) or exercise test duration (Ades, Waldmann, and Gillespie, 1995; Ben-Ari, Rothbaum, Linnemeir, et al., 1989; Dressendorfer, Franklin, Smith, et al., 1993; Hands, Briffa, Henderson, et al., 1987; Heath, Maloney, and Fure, 1987; Kavanagh, Yacoub, Mertens, et al., 1988; Milani, Littman, and Lavie, 1993; Roviaro, Holmes, and Holmsten, 1984; Stevens and Hanson, 1984; Stuart, Koyal, Lundstrom, et al., 1985); and increased muscular strength and/or (Sparling, Cantwell, Dolan, et al., 1990; Stewart, Mason, and Kelemen, 1988). Improvement in measures of exercise tolerance were reported in seven of the nine nonrandomized controlled trials that involved patients after myocardial infarction, in five of six that involved patients after CABG, in all 10 trials that involved patients with varied presentations of coronary disease, and in each of the trials in patients after PTCA and after cardiac transplantation. Comparable improvements in measures of exercise tolerance were reported in patients following myocardial infarction and in coronary-prone patients (Ribiero, Hartley, Sherwood, et al., 1984).

The duration of exercise training in the nonrandomized controlled trials was variable, with the most common duration being 8-12 weeks. One study reported improved aerobic fitness after 4-5 weeks of supervised exercise in propranolol-treated patients with coronary disease (p < .05) (Stuart, Koyal, Lundstrom, et al., 1985). Eight nonrandomized controlled studies involved 8-12 weeks of exercise training (Ades, Waldmann, and Gillespie, 1995; Ben-Ari, Rothbaum, Linnemeir, et al., 1989; Hands, Briffa, Henderson, et al., 1987; Heath, Maloney, and Fure, 1987; Hedback, Perk, Engvall, et al., 1990; Jugdutt, Michorowski, and Kappagoda, 1988; Roviaro, Holmes, and Holmsten, 1984; Stevens and Hanson, 1984). Six of these studies showed statistically significant improvements in exercise tolerance (Ades, Waldmann, and Gillespie, 1995; Ben-Ari, Rothbaum, Linnemeir, et al., 1989; Hands, Briffa, Henderson, et al., 1987; Heath, Maloney, and Fure, 1987; Roviaro, Holmes, and Holmsten, 1984; Stevens and Hanson, 1984). Six studies described exercise training durations of 13-26 weeks Cardus, McTaggart, and Ribas-Cardus, 1980; Hoffmann, Duba, Lengyel, et al., 1987; Raineri, Assennato, Candela, et al., 1982; Ribiero, Hartley, Sherwood, et al., 1984; Sparling, Cantwell, Dolan, et al., 1990; Stuart, Koyal, Lundstrom, et al., 1985); all of them reported statistically significant improvements in measures of cardiorespiratory fitness. All five nonrandomized controlled exercise-training studies that lasted 6 months to 1 year reported improvements in measures of exercise tolerance Hedback and Perk, 1987; Hedback, Perk, and Engvall, 1992; Milani, Littman, and Lavie, 1993; Naughton, Bruhn, and Lategola, 1968; Schuler, Hambrecht, Schlierf, et al., 1992b). Two of the four nonrandomized controlled studies of exercise training for more than 1 year showed significant improvements in exercise tolerance (p < .01, Carson, Phillips, Lloyd, et al., 1982; p < .05, Schuler, Hambrecht, Schlierf, et al., 1992b). However, two studies that involved primarily home exercise reported no significant effect of exercise training selected measures of aerobic fitness ( Hedback, Perk, Engvall, et al., 1990; Perk, Hedback, and Jutterdal, 1989).

Four long-term (≥1 year) studies that involved 3 or fewer months of supervised exercise training followed by home exercise reported no significant effect of exercise training on selected measures of exercise tolerance in exercising versus nonexercising patients (Hedback and Perk, 1990; Hedback, Perk, and Engvall, 1992; Hedback, Perk, Engvall, et al., 1990; Perk, Hedback, and Jutterdal, 1989). However, these serial reports by the same investigators represent a single expanding or reanalyzed data set.

A nonrandomized controlled trial that included coronary risk reduction in addition to exercise training documented significantly lower participation rates for older compared with younger patients (p < .05; Ades, Waldmann, and Gillespie, 1995). There was comparable improvement in exercise capacity (p < .0001 vs. baseline) between older and younger age groups, as well as comparable improvement in several coronary risk factors (p < .01 vs. baseline) in both elderly and younger patients.

Exercise training increased exercise duration in elderly coronary patients (p < .05) compared with a nonrandomized control patient group at both 3 and 12 months, despite the fact that over half of the control patients reported walking regularly (Ades, Waldmann, and Gillespie, 1995). Patient groups that were older and younger than age 70 years had comparable improvement in exercise tolerance, and elderly patients of both genders had comparable improvement ( Ades, Waldmann, and Gillespie, 1995).

#### Observational Studies

Forty-three observational studies addressed exercise tolerance as an outcome of cardiac rehabilitation exercise training. All of these studies reported statistically significant improvement in exercise tolerance after exercise training compared with baseline. Exercise training durations were 6-21 months Ades and Grunvald, 1990; Ades, Hanson, Gunther, et al., 1987; Ades, Huang, and Weaver, 1992; Ades, Waldmann, Poehlman, et al., 1993; Arvan, 1988; Barletta, Fattirolli, Bisi, et al., 1983; Braun, Parcels, Brooks, et al., 1989; Burns, Bogenhagen, Dykstra, et al., 1991; Butler, Beierwaltes, and Rogers, 1987; Cannistra, Balady, O'Malley, et al., 1992; Crozier Ghilarducci, Holly, and Amsterdam, 1989; Ehrman, Keteyian, Fedel, et al., 1992; Ehsani, Heath, Hagberg, et al., 1981; Ehsani, Martin, Heath, et al., 1982; Ferguson, Petitclerc, Choquette, et al., 1974; Fletcher, Cantwell, and Watt, 1979; Hammond, Kelly, Froelicher, et al., 1985; Hartung and Rangel, 1981; Heath, Ehsani, Hagberg, et al., 1983; Ignone, Giordano, and Tavazzi, 1988; Jensen, Atwood, Froelicher, et al., 1980; Kavanagh, Yacoub, Mertens, et al., 1989; Kellermann, Ben-Ari, Chayet, et al., 1977; Kellermann, Shemesh, Fisman, et al., 1990; Kennedy, Spiekerman, Lindsay, et al., 1976; Keteyian, Ehrman, Fedel, et al., 1990; Lavie, Milani, and Littman, 1993; Lee, Ice, Blessey, et al., 1979; Letac, Cribier, and Desplanches, 1977; Maresh, Harbecht, Flick, et al., 1985; Monpere, Francois, Brochier, et al., 1988; Redwood, Rosing, and Epstein, 1972; Smith, Layton, Newmark, et al., 1987; Stevenson, Steimle, Fonarow, et al., 1995; Streja and Mymin, 1979; Sullivan, Higginbotham, and Cobb, 1988; Sullivan, Higginbotham, and Cobb, 1989; Superko, 1983; Tubau, Witztum, Froelicher, et al., 1982; Verani, Hartung, Hoepfel-Harris, et al., 1981; Waites, Watt, and Fletcher, 1983; Williams, Maresh, Esterbrooks, et al., 1985; Zohman and Tobis, 1967). Given the lack of control populations, no causal relationship between exercise training and improved exercise tolerance could be established from observational study data. A recent study involved ambulatory patients with severe left ventricular systolic dysfunction who were awaiting cardiac transplantation; optimal pharmacologic therapy was combined with nonsupervised walking for a target duration of 20-30 minutes or 2 miles four or more times per week for an average of 6 months. Thirty-eight of 68 patients had a significant increase in peak oxygen uptake and exercise performance, with 31 of these 38 removed from the transplantation list with excellent early survival Stevenson, Steimle, Fonarow, et al., 1995).

### Other Issues

The use of beta-blocking drugs in patients following myocardial infarction did not impair improvement in exercise tolerance following cardiac rehabilitation exercise training Dressendorfer, Smith, Hollingsworth, et al., 1990; Pratt, Welton, Squires, et al., 1981; Stuart, Koyal, Lundstrom, et al., 1985; Vanhees, Fagard, Amery, et al., 1984).

One study examined the influence of psychological dysfunction on exercise training response (Milani, Littman, and Lavie, 1993). The increases in aerobic capacity after exercise training in coronary patients with and without depressive symptoms were 12 percent and 26 percent, respectively, which suggests that clinical depression predicts a less favorable improvement in exercise tolerance (p < .05).

Studies of cardiac rehabilitation exercise training in older patients are reported later in this chapter. Studies of home versus supervised cardiac rehabilitation exercise training are reported in Chapter 4. The setting and extent of surveillance for the implementation of cardiac rehabilitation exercise training are also addressed in Chapter 4. Several recent randomized and nonrandomized controlled trials compared supervised exercise with home-based or remote exercise using transtelephonic ECG monitoring or compared the outcome of home-based, transtelephonic ECG-monitored exercise with a nonexercise control group (see Chapter 4).

### Conclusions

The scientific data clearly establish that improvements in objectively measured exercise tolerance result from cardiac rehabilitation exercise training; therefore, appropriately prescribed and conducted exercise training should be a key component of cardiac rehabilitation services for coronary patients with angina pectoris, myocardial infarction, CABG, and PTCA as well as for patients with compensated heart failure or with a decreased ventricular ejection fraction. This approach is particularly important for patients with decreased functional capacity.

The beneficial effect of cardiac rehabilitation exercise training on exercise tolerance is one of the most clearly established favorable outcomes in the panel's review. The large number of studies that reported a favorable outcome allowed the panel to ascertain the characteristics of exercise training that resulted in improved exercise tolerance. The most consistent benefit appeared to occur with exercise training at least three times per week for 12 or more weeks' duration. The duration of aerobic exercise training sessions varied from 20 to 40 minutes, at an intensity approximating 70-85 percent of the baseline maximal exercise test heart rate.

No statistically significant increase in cardiovascular complications or other serious adverse outcomes was reported in any randomized controlled trials that evaluated the role of exercise training in patients with coronary disease. These trials included patients with various manifestations of coronary disease including myocardial infarction, CABG, and PTCA. The randomized controlled trials that reported exercise tolerance as an outcome of exercise training studied 3,932 patients following myocardial infarction, 745 patients with catheterization-documented coronary disease, 215 patients following CABG, and 139 patients following PTCA. No deterioration in measures of exercise tolerance were reported in any patients undergoing exercise training, nor did any controlled studies document significantly greater improvement in measures of exercise tolerance favoring control versus exercising patient groups. Further details regarding the safety of exercise training are found in later sections of this chapter (see Morbidity and Safety Issues; Mortality and Safety Issues) and in Chapter 4.

## Strength Training

RECOMMENDATION: Strength training improves skeletal muscle strength and endurance in clinically stable coronary patients. Training measures designed to increase skeletal muscle strength can safely be included in the exercise-based rehabilitation of clinically stable coronary patients, when appropriate instruction and surveillance are provided.

### Scientific Evidence (Strength of Evidence = B)

The scientific evidence regarding the application of testing or strength training in the rehabilitation of patients with coronary disease was derived from 12 studies that involved 242 patients.

Seven studies involved strength training Butler, Palmer, and Rogers, 1992; Crozier Ghilarducci, Holly, and Amsterdam, 1989; Kelemen, 1989; McCartney, McKelvie, Haslam, et al., 1991; Sparling, Cantwell, Dolan, et al., 1990; Stewart, Mason, and Kelemen, 1988; Wilke, Sheldahl, Levandoski, et al., 1991), and five were reports of cross-sectional comparisons of strength testing versus treadmill exercise testing, with and without weight loading or weight carrying (Amos, Porcari, Bauer, et al., 1992; Faigenbaum, Skrinar, Cesare, et al., 1990; Featherstone, Holly, and Amsterdam, 1993; Schram and Hanson, 1988; Sheldahl, Wilke, Tristani, et al., 1983).

The seven strength-training studies included four randomized controlled trials ( Butler, Palmer, and Rogers, 1992; Kelemen, 1989; McCartney, McKelvie, Haslam, et al., 1991; Wilke, Sheldahl, Levandoski, et al., 1991) and three nonrandomized controlled studies ( Crozier Ghilarducci, Holly, and Amsterdman, 1989; Sparling, Cantwell, Dolan, et al., 1990; Stewart, Mason, and Kelemen, 1988). In most of these studies, circuit weight training was added to the exercise regimens of coronary patients who had already participated in aerobic exercise training, generally for 3 months or more. All seven strength-training studies involved male patients exclusively, up to 70 years of age (mean age in the 50s). Three 30-to 60-minute strength-training exercise sessions were typically undertaken each week. The duration of strength training varied from 6 to 26 weeks; intensity prescriptions ranged from 25 to 80 percent of the one-repetition maximal (the maximal effort an individual could perform during a resistance task in one full range of motion), also known as the maximal voluntary contraction. All studies demonstrated significant improvements in measures of weight-carrying tolerance (time) or increases in skeletal muscle strength after completion of resistance training. There was comparable benefit with high- and low-resistance training (Crozier Ghilarducci, Holly, and Amsterdman, 1989; Kelemen, 1989).

Three randomized controlled trials also evaluated aerobic exercise tolerance by exercise testing before and after strength training (Butler, Palmer, and Rogers, 1992; Kelemen, 1989; McCartney, McKelvie, Haslam, et al., 1991). Two demonstrated an improvement in exercise duration that was significantly greater with strength training than with aerobic exercise alone (Kelemen, 1989; McCartney, McKelvie, Haslam, et al., 1991). The other study reported no significant difference Butler, Palmer, and Rogers, 1992 ).

The five strength-testing studies demonstrated that submaximal and peak resistance exercise, using a variety of resistance-training devices, resulted in significantly lower peak heart rate, rate-pressure product, and oxygen consumption responses than did maximal treadmill exercise testing. Moreover, angina, ventricular arrhythmias, and ischemic ST-segment depression occurred less frequently during resistance testing than during aerobic exercise testing to volitional fatigue (Faigenbaum, Skrinar, Cesare, et al., 1990; Featherstone, Holly, and Amsterdam, 1993; Sheldahl, Wilke, Tristani, et al., 1983).

### Conclusions

These studies demonstrate the effectiveness of resistance exercise training in selected patients with coronary disease. The absence of signs or symptoms of myocardial ischemia, abnormal hemodynamic changes, and cardiovascular complications in these studies, with one possible exception of an uncomplicated reinfarction that occurred 90 minutes following exercise training (Crozier Ghilarducci, Holly, and Amsterdam, 1989), suggests that resistance exercise training is safe for selected coronary patients who have previously participated in rehabilitative aerobic exercise training. Improvement in muscle strength could benefit patients' performance of activities of daily living (Leon, Certo, Comoss, et al., 1990). However, most of the studies involved small numbers of "low-risk" male patients, age 70 years or younger, with minimal functional aerobic impairment and with normal or near-normal left ventricular function; also, training was of relatively short duration (12 weeks or less). The lack of cardiovascular and orthopedic complications in the 3-year followup of strength training was largely attributed to strict preliminary screening and careful supervision Stewart, Mason, and Kelemen, 1988 ). The extent to which the safety and effectiveness demonstrated by these studies can be extrapolated to other populations of coronary or cardiac patients (e.g., women, older patients of both genders with low aerobic fitness, patients at moderate-to-high cardiovascular risk) requires study. The panel notes, however, a prospective observational study of community-dwelling men and women, 75 years of age and older, that documented significant improvement in survival in both men and women who were current participants in regular exercise at least three times per week Langer, Klauber, Criqui, et al., 1994). A study of elderly subjects in their 90s, in a noncardiac rehabilitation setting, showed that high-intensity strength training improved skeletal muscle functional capacity and measures of strength Fiatarone, Marks, Ryan, et al., 1990), an important feature in that elderly patients with decreased functional capacity and muscle strength may derive particular benefit.

## Exercise Habits

RECOMMENDATION: Cardiac rehabilitation exercise training promotes increased participation in exercise in addition to rehabilitation exercise training in patients after myocardial infarction or CABG. This effect does not persist long-term after completion of exercise rehabilitation. Long-term cardiac rehabilitation exercise training is recommended to provide the benefit of enhanced physical activity and exercise habits.

### Scientific Evidence (Strength of Evidence = B)

The scientific evidence for the relationship between exercise training and subsequent exercise habits includes 10 randomized controlled trials (Bengtsson, 1983; DeBusk, Houston, Haskell, et al., 1979; Engblom, Hietanen, Hamalainen, et al., 1992; Erdman, Duivenvoorden, Verhage, et al., 1986; Hamalainen, Luurila, Kallio, et al., 1989; Hambrecht, Niebauer Marburger, et al., 1993; Ornish, Brown, Scherwitz, et al., 1990; Roman, Gutierrez, Luksic, et al., 1983; Sivarajan, Bruce, Lindskog, et al., 1982; Todd, and Ballatyne, 1992), two nonrandomized controlled studies Ben-Ari, Rothbaum, Linnemeier, et al., 1992; Heath, Maloney, and Fure, 1987), and three observational studies ( Ades, Huang, and Weaver, 1992; Ewart, Stewart, Gillilan, et al., 1986; Kinsey, Fletcher, Rice, et al., 1989). Most of the studies involved patients following myocardial infarction and included predominantly male patients under the age of 65 years, thereby limiting the generalizability of the data.

Six of the randomized controlled trials showed a significant increase in subsequent exercise habits in exercise-trained patients (Erdman, Duivenvoorden, Verhage, et al., 1986; Hambrecht, Niebauer, Marburger, et al., 1993; Ornish, Brown, Scherwitz, et al., 1990; Roman, Gutierrez, Luksic, et al., 1983; Sivarajan, Bruce, Lindskog, et al., 1982; Todd and Ballatyne, 1992). The beneficial outcomes of exercise habits were maintained for up to 1 year in long-term exercise rehabilitation (Hambrecht, Niebauer, Marburger, et al., 1993; Ornish, Brown, Scherwitz, et al., 1990; Todd and Ballatyne, 1992), but these habits were not maintained at the 5-year followup after completion of exercise rehabilitation ( Erdman, Duivenvoorden, Verhage, et al., 1986). Four of the randomized controlled trials reported no significant differences in subsequent exercise habits (Bengtsson, 1983; DeBusk, Houston, Haskell, et al., 1979; Engblom, Hietanen, Hamalainen, et al., 1992; Hamalainen, Luurila, Kallio, et al., 1989).

Both nonrandomized controlled studies documented a statistically significant increase in levels of self-reported exercise in the exercise versus usual care groups (Ben-Ari, Rothbaum, Linnemeier, et al., 1992; Heath, Maloney, and Fure, 1987), with no difference between gymnasium- and home exercise-training groups Heath, Maloney, and Fure, 1987).

One observational study demonstrated no favorable effect of exercise training on subsequent exercise habits Kinsey, Fletcher, Rice, et al., 1989), another observational study described a correlation between patients' high jogging self-efficacy and their exceeding the recommended target heart rate range for exercise (Ewart, Stewart, Gillilan, et al., 1986), and another observational study documented a decreased participation in exercise rehabilitation by elderly women compared with elderly men ( Ades, Waldmann, Polk, et al., 1992).

### Conclusions

There is suggestive evidence that exercise training enhances subsequent exercise habits. A limitation of the scientific data relating to continued exercise habits as a result of rehabilitative exercise training is the self-report nature of the information, which was typically based on questionnaire or physical activity diary data. Information concerning the cardiovascular benefits of varied exercise and recreational physical activities is sparse in the cardiac rehabilitation literature. However, extensive studies and position statements in populations without apparent heart disease document that regular exercise, including a wide scope of physical activities with a broad range of intensity and duration, have beneficial effects on overall health, morbidity, and mortality (American Heart Association, 1992; Blair, Khol, Paffenberger, et al., 1989; Pate, Pratt, Blair, et al., 1995). Patients should be encouraged to undertake exercise activities following cardiac exercise rehabilitation that are personally enjoyable and that can be sustained long-term.

The panel endorses the position statement of the AHA regarding the beneficial role of physical activity, that "regular aerobic physical activity increases exercise capacity and plays a role in both primary and secondary prevention of cardiovascular disease" American Heart Association, 1992 ). In addition, the recommendations from the Centers for Disease Control and Prevention and the American College of Sports Medicine (ACSM) are endorsed regarding the value of modest intensity habitual physical activity for all Americans (Pate, Pratt, Blair, et al., 1995). The panel also recognizes the need to encourage women, particularly older women, to participate in cardiac rehabilitation programs designed to enhance exercise capacity and physical activity.

## Symptoms

RECOMMENDATION: Exercise rehabilitation decreases angina pectoris in patients with coronary disease and decreases symptoms of heart failure in patients with left ventricular systolic dysfunction. Exercise training is recommended as an integral component of the symptomatic management of these patients.

### Scientific Evidence (Strength of Evidence = B)

Twenty-six scientific studies reported the effect of cardiac rehabilitation exercise training on symptoms. Twelve were randomized controlled trials, seven were nonrandomized controlled studies, and seven were observational reports.

Eight of the 12 randomized controlled trials reported statistically significant improvement in cardiovascular symptoms in intervention groups compared with control groups. Seven of these trials involved exercise training as the sole intervention Carson, Phillips, Lloyd, et al., 1982; Coats, Adamopoulos, Meyer, et al., 1990; Froelicher, Jensen, Genter, et al., 1984; Meyer, Casadei, Coats, et al., 1991; Roman, Gutierrez, Luksic, et al., 1983; Todd and Ballatyne, 1992; Vermeulen, Lie, and Durrer, 1983), and one trial was multifactorial (Ornish, Brown, Scherwitz, et al., 1990). Four randomized controlled trials of exercise training reported no significant difference in cardiovascular symptoms between the exercise and control groups ( Erdman, Duivenvoorden, Verhage, et al., 1986; Kallio, Hamalainen, Hakkila, et al., 1979; Marra, Paolillo, Spadaccini, et al., 1985; Mayou, MacMahon, Sleight, et al., 1981); two of these trials were multifactorial (Kallio, Hamalainen, Hakkila, et al., 1979; Marra, Paolillo, Spadaccini, et al., 1985), and two involved only exercise Erdman, Duivenvoorden, Verhage, et al., 1986; Mayou, MacMahon, Sleight, et al., 1981). Two of the 12 randomized controlled trials involved patients with symptomatic left ventricular dysfunction Coats, Adamopoulos, Meyer, et al., 1990; Meyer, Casadei, Coats, et al., 1991); all others dealt with patients with angina pectoris.

Six of the seven nonrandomized controlled studies reported statistically significant improvements in cardiovascular symptoms favoring rehabilitation versus control groups; three involved exercise training as the sole intervention Hedback, Perk, Engvall, et al., 1990; Hertzeanu, Shemesh, Aron, et al., 1993; Naughton, Bruhn, and Lategola, 1968), and three were multifactorial (Ben-Ari, Kellermann, Fisman, et al., 1986; Ben-Ari, Rothbaum, Linnemeier, et al., 1992; Ribiero, Hartley, Sherwood, et al., 1984). One nonrandomized controlled study of exercise training in patients with baseline diminished left ventricular ejection fraction following a large anterior myocardial infarction reported worsening symptomatic status in the rehabilitation versus control patients ( Jugdutt, Michorowski, and Kappagoda, 1988).

Six of the seven observational studies reported improved cardiovascular symptoms following exercise training Kennedy, Spiekerman, Lindsay, et al., 1976; Lee, Ice, Blessey, et al., 1979; Letac, Cribier, and Desplanches, 1977; Smith, Layton, Newmark, et al., 1987; Verani, Hartung, Hoepfel-Harris, et al., 1981; Zohman and Tobis, 1967), and one reported no improvement ( Ignone, Giordano, and Tavazzi, 1988). All but one of the observational studies involved patients with angina pectoris; one study involved patients with symptoms of heart failure (Lee, Ice, Blessey, et al., 1979).

### Conclusions

There is moderate evidence for improvement in cardiovascular symptomatic status, both angina pectoris and heart failure symptoms, as a result of cardiac rehabilitation exercise training.

Symptomatic outcomes in these scientific studies were confounded by inadequate information regarding changes in medication status, by differing levels of exercise or physical activity at baseline and at followup, as well as by nonrehabilitation exercise activities of control patients. Change in symptomatic status of cardiac patients often results in changes in medication regimens.

The panel noted the relatively young age of patients studied; only two studies included patients who were older than 65 years of age. Only 8 of the 20 controlled trials included women; and in these studies, only a small proportion of the enrollees were women -- less than 25 percent. No study reported symptomatic outcomes by gender or age.

## Smoking

RECOMMENDATION: Exercise training has little or no effect on smoking cessation. Smoking cessation is achieved by specific smoking cessation strategies.

### Scientific Evidence (Strength of Evidence = B)

The data pertaining to the effect of exercise rehabilitation smoking habits included 12 randomized controlled trials, 8 nonrandomized controlled studies, and 4 observational reports. Three of the 12 randomized controlled trials involved exercise training as the sole intervention. None of these studies reported statistically significant differences in self-reported smoking cessation rates between intervention and control patients Carson, Phillips, Lloyd, et al., 1982; Erdman, Duivenvoorden, Verhage, et al., 1986; Roman, Gutierrez, Luksic, et al., 1983). One randomized controlled trial evaluated exercise training versus exercise training plus education/counseling versus a control group of patients after myocardial infarction Sivarajan and Newton, 1984); there was no significant difference in self-reported smoking cessation or reduction in self-reported smoking habits at the 3- and 6-month followups.

Eight randomized controlled trials involved multifactorial cardiac rehabilitation, which made it impossible to ascertain an independent effect on smoking cessation attributable to exercise training. Two trials reported statistically significant reduction in smoking rates favoring rehabilitation versus control groups, one by self-report (Engblom, Ronnemaa, Hamalainen, et al., 1992) and the other using biochemically confirmed smoking cessation data (DeBusk, Houston Miller, Superko, et al., 1994); the latter used nicotine gum or patch in addition to behavioral approaches for smoking cessation. Another randomized controlled trial reported no difference in self-reported smoking cessation rates in intervention patients compared with control patients, although the self-reported daily cigarette consumption averaged 11 in the exercise compared with 22 in the nonexercise group (p < .03; Taylor, Houston-Miller, Haskell, et al., 1988). Five trials reported no significant difference in self-reported smoking cessation rates between intervention and control groups Hamalainen, Luurila, Kallio, et al., 1989; Kallio, Hamalainen, Hakkila, et al., 1979; Schuler, Hambrecht, Schlierf, et al., 1992b; Vermeulen, Lie, and Durrer, 1983) or in biochemically verified smoking cessation rates (Haskell, Alderman, Fair, et al., 1994).

All eight nonrandomized controlled studies described smoking cessation rates that were based on self-report; five of these reported significantly greater cessation rates favoring rehabilitation versus nonrandomized control patients Ben-Ari, Kellermann, Fisman, et al., 1986; Ben-Ari, Rothbaum, Linnemeier, et al., 1989; Ben-Ari, Rothbaum, Linnemeier, et al., 1992; Hedback and Perk, 1987; Hedback, Perk, Engvall, et al., 1990); all but one were multifactorial rehabilitation interventions (Hedback, Perk, Engvall, et al., 1990). Three involved exercise training and counseling (Ben-Ari, Rothbaum, Linnemeir, et al., 1989; Ben-Ari, Rothbaum, Linnemeir, et al., 1992; Hedback and Perk, 1987). Two studies reported no significant difference between groups Amos, Porcari, Bauer, et al., 1992; Perk, Hedback, and Jutterdal, 1989). A final nonrandomized controlled study reported equal smoking cessation rates by self-report, whether or not patients were classified as depressed at baseline (Milani, Littman, and Lavie, 1993).

All four observational studies reported statistically significant reductions in self-reported smoking habits at the completion of cardiac rehabilitation ( Kinsey, Fletcher, Rice, et al., 1989; Monpere, Francois, Brochier, et al., 1988; Shephard, Corey, and Kavanagh, 1981; Waites, Watt, and Fletcher, 1983).

### Conclusions

Little or no evidence was found of beneficial outcome in smoking cessation resulting from exercise training as a sole intervention. Given the documented benefit of smoking cessation in decreasing coronary risk, specific techniques of proven value in effecting smoking cessation should be incorporated into multifactorial cardiac rehabilitation; studies reporting changes in smoking habits should include biochemical confirmation ( Jonas, Oates, Ockene, et al., 1992).

Most of the smoking cessation studies that were reviewed involved patients who were younger than 65 years of age, predominantly patients following myocardial infarction. No study included more than 25 percent female patients. None of the trials reported smoking cessation outcomes by gender or by age.

## Lipids

RECOMMENDATION: Cardiac rehabilitation exercise training is not recommended as a sole intervention for lipid modification because of its inconsistent effect on lipid and lipoprotein levels. Optimal lipid management requires specifically directed dietary and, as medically indicated, pharmacologic management, in addition to cardiac rehabilitation exercise training.

### Scientific Evidence (Strength of Evidence = B)

Thirty-seven reports in the scientific literature describe changes in various lipid levels and/or lipoprotein levels resulting from exercise-based cardiac rehabilitation. Eighteen were randomized controlled trials, 6 were nonrandomized controlled studies, and 13 were observational reports.

The randomized controlled trials are described in Table 4. Twelve of these trials involved multifactorial rehabilitation, with nine reporting improvement in total cholesterol levels favoring intervention versus control patients ( DeBusk, Houston Miller, Superko, et al., 1994; Hambrecht, Niebauer, Marburger, et al., 1993; Haskell, Alderman, Fair, et al., 1994; Ornish, Brown, Scherwitz, et al., 1990; Ornish, Scherwitz, Doody, et al., 1983; Plavsic, Turkulin, Perman, et al., 1976; Schuler, Hambrecht, Schlierf, et al., 1992b; Vermeulen, Lie, and Durrer, 1983; Watts, Lewis, Brunt, et al., 1992). One study did not report a test of statistical significance for cholesterol lowering ( Plavsic, Turkulin, Perman, et al., 1976), and one reported favorable reduction in cholesterol levels only in patients who were provided cholesterol-lowering medication (Hamalainen, Lurrila, Kallio, et al., 1989). Two trials did not report significant differences between intervention and control patients (Fletcher, Dunbar, Felner, et al., 1994; Nikolaus, Schlierf, Vogel, et al., 1991). Two of the six studies that used exercise training as the sole intervention documented statistically significant improvement in total cholesterol levels favoring exercise-trained versus control patients (Kallio, Hamalainen, Hakkila, et al., 1979; Roman, Gutierrez, Luksic, et al., 1983), and four studies reported no significant difference between exercise-trained and control patients (Carson, Phillips, Lloyd, et al., 1982; Engblom, Hietanen, Hamalainen, et al., 1992; Oberman, Cleary, Larosa, et al., 1982; Wilhelmsen, Sanne, Elmfeldt, et 1975).

Table 4. Effect of exercise rehabilitation on lipid parameters: Randomized controlled trials

Reference, Country | Patients | Intervention, Followup | | Outcome (values in mg/dL)
Wilhelmsen, Sanne, Elmfeldt, et al. (1975) Sweden | Sample size: 228 Gender: 100% men Age: Mean 50.6 years Category: 89% after MI | Intervention: Supervised aerobic exercise Followup: 1 year | | Mean total cholesterol: Intervention 276 to 262, Control 273 to 261 Mean triglyceride: Intervention 148 to 127, Control 159 to 131 All ps < .05 vs. baseline; no significant differences intervention vs. control
Plavsic, Turkulin, Perman, et al. (1976) Yugoslavia | Sample size: 483 Gender: 100% men Age: < 59 years Category: CHD or coronary prone | Intervention: Supervised exercise. Exercise group and control group received diet, lifestyle, drug therapy. Followup: 6 and 12 months | | Mean total cholesterol at 6 months: Intervention 242 to 221, Control 228 to 246 Mean total cholesterol at 12 months: Intervention 250 to 227, Control 244 to 233 No p values given
Kallio, Hamalainen, Hakkila, et al. (1979) Finland | Sample size: 375 Gender: 301 men, 74 women Age: < 65 years, mean 54 years Category: MI | Intervention: Supervised cycle exercise Followup: 3 years | | Mean total cholesterol at 1 year: Intervention 232 to 251, Control 232 to 282 Mean total cholesterol at 3 years: Intervention 232 to 255, Control 232 to 286, p < .001 between groups
Carson, Phillips, Lloyd, et al. (1982) United Kingdom | Sample size: 303 Gender: 100% men Age: Not specified Category: 8 weeks after MI, clinically low risk | Intervention: Aerobic gymnasium exercise Followup: 2 years | | Mean triglyceride: Intervention 182 to 144, Control no change, p < .05 between groups Mean total cholesterol: No significant change from baseline in either group
Oberman, Cleary, Larosa, et al. (1982) United States | Sample size: 651 Gender: 100% men Age: 30-64 years Category: CHD, 80% prior MI, 6 or more months previously | Intervention: Supervised aerobic exercise Followup: 1 year | | Mean total cholesterol: No significant change from baseline in either group Mean triglyceride: Intervention 143 to 139, Control 146 to 155, p < .04 between groups
Vermeulen, Lie, and Durrer (1983) The Netherlands | Sample size: 78 Gender: 100% men Age: 40-55 years Category: MI | Intervention: Multifactorial. Exercise training but details not specified. Followup: 5 years | | Total cholesterol: Intervention 271 to 255 Control 278 to 276, p < .005 between groups
Roman, Gutierrez, Luksic, et al. (1983) Chile | Sample size: 193 Gender: 174 men, 19 women Age: Mean 56 years rehabilitation, 59 years control Category: First transmural acute MI | Intervention: Aerobic exercise Followup: 6-108 months, mean 42 months | | Authors stated "no statistically significant change in hyperlipidemia" in controls, but "significant reduction in cholesterol in intervention subjects." No p values given.
Ornish, Scherwitz, Doody, et al. (1983) United States | Sample size: 46 Gender: 41 men, 5 women Age: Not specified Category: Stable catheterization-documented CHD | Intervention: Residential program. Stress management, aerobic exercise, vegetarian diet, social support. Followup: 24 days | | Mean total cholesterol: Intervention 229 to 182, Control 220 to 215, p < .001 between groups Mean triglyceride: Intervention 189 to 160, Control 246 to 248, p < .01 between groups Mean HDL cholesterol: Intervention 47 to 39, Control 39 to 38, p < .001 between groups
Hamalainen, Luurila, Kallio, et al. (1989) Finland | Sample size: 375 Gender: 301 men, 74 women Age: < 65 years Category: MI | Intervention: Multifactorial. Supervised exercise training, counseling, diet, and medication for lipid-lowering. Followup: 3 years | | Total cholesterol significantly less in patients receiving lipid-lowering medication, but not in patients without lipid- lowering medication at year 3 Triglyceride values significantly less in intervention patients at years 1 and 2
Ornish, Brown, Scherwitz, et al. (1990) United States | Sample size: 48 Gender: 88% men Age: 56-60 years Category: Catheterization-documented CHD | Intervention: Multifactorial. Stringent diet, stress management, aerobic exercise. Followup: 1 year | | Mean total cholesterol: Intervention 228 to 174, Control 243 to 232, p = .001 between groups Mean LDL cholesterol: Intervention 151 to 97, Control 166 to 159, p = .001 between groups HDL cholesterol and triglycerides, nonsignificant difference between groups. LDL:HDL ratio decreased from 4.2 to 2.9 in intervention vs. 3.6 to 3.3 in control group. p = 0.007 between groups.
Nikolaus, Schlierf, Vogel, et al. (1991) Germany | Sample size: 45 Gender: 100% men Age: Not specified Category: Stable angina pectoris and catheterization-documented CHD | Intervention: Supervised exercise + diet Followup: 1 year | | Mean triglyceride: Intervention 202 to 141 (p = 0.03), Control no significant change Mean HDL cholesterol: Intervention 35.6 to 40.4 (no p value reported), Control no data provided Total and LDL cholesterol: No significant change in either group
Engblom, Hietanen, Hamalainen, et al. (1992) Finland | Sample size: 201 Gender: 88% men Age: < 65 years Category: CABG | Intervention: Supervised exercise Followup: 12 months | | Total cholesterol and triglyceride significantly decreased from baseline both groups, but no significant difference between groups HDL cholesterol significantly increased from baseline exercise group only, but no significant difference between groups Ratio total:HDL cholesterol significantly higher in both groups compared with baseline, but no significant difference between groups
Watts, Brunt, et al. (1992) United Kingdom | Sample size: 74 Gender: 100% men Age: < 66 years, mean 50 years Category: Stable angina and catheterization-documented CHD | Intervention: Exercise + diet, exercise plus diet and cholestyramine medication vs. no- intervention controls Followup: Mean 39 months | | Mean total cholesterol: Exercise and diet 278 to 239*, Exercise, diet, and cholestyramine 288 to 215*, Control 273 to 268 Mean LDL cholesterol: Exercise and diet 194 to 162*, Exercise, diet, and cholestyramine 203 to 130*, Control 187 to 181* *p < .005 either treatment group vs. control Mean HDL cholesterol: Exercise and diet 44.1 to 44.1, Exercise, diet, and cholestyramine 48.0 to 46.1, Control 47.2 to 46.8 HDL changes not significant
Schuler, Hambrecht, Schlierf, et al. (1992b) Germany | Sample size: 92 Gender: 100% men Age: Mean 53 years Category: Catheterization-documented stable CHD | Intervention: Exercise and diet Followup: 1 year | | Mean total cholesterol: Intervention 234 to 211, Control 236 to 236, p < .05 between groups Mean LDL cholesterol: Intervention 164 to 149, Control 164 to 168, p < .05 between groups No significant difference in HDL cholesterol between groups Mean triglyceride: 24% reduction intervention vs. control (p < .001 between groups)
Hambrecht, Niebauer, Marburger, et al. (1993) Germany | Sample size: 88 Gender: 100% men Age: Mean 54 years Category: Catheterization-documented stable angina and CHD | Intervention: Supervised home exercise and diet Followup: 1 year | | Mean total cholesterol: Intervention 236 to 213, Control 230 to 233, p < .001 between groups Mean LDL cholesterol: Intervention 167 to 152, Control 160 to 167, p < .001 between groups No significant difference in HDL cholesterol between groups. Triglycerides decreased comparably in intervention and controls (21% vs. 17%), without significant difference between groups.
DeBusk, Houston Miller, Superko, et al. (1994) United States | Sample size: 585 Gender: 79% men Age: < 70 years, mean 57 years Category: MI | Intervention: Intensive multifactorial risk reduction with home exercise training and lipid-lowering drugs when indicated Followup: 1 year | | Mean total cholesterol: Intervention 208 to 185, Control 203 to 209, p < .001 between groups Mean LDL cholesterol: Intervention 140 to 107, Control 136 to 132, p < .001 between groups No significant difference between groups in HDL cholesterol or triglyceride
Haskell, Alderman, Fair, et al. (1994) United States | Sample size: 300 Gender: 83% men intervention, 92% men usual care Age: < 75 years, mean 57 years Category: Catheterization-documented CHD including CABG, PTCA | Intervention: Home rehabilitation. Multifactorial + lipid- lowering medications Individual therapy guided by nurse manager including diet intervention, behavioral management for smoking cessation, and lipid-lowering medication. Individual home exercise training with transtelephonic ECG monitoring. Followup: 4 years | | Mean total cholesterol: Intervention 232 to 193, Control 228 to 224, p = .001 between groups Mean LDL cholesterol: Intervention 159 to 120, Control 155 to 151, p = .001 between groups Mean HDL cholesterol: Intervention 46.1 to 51.5, Control 42.3 to 44.9, p = . 001 between groups Triglyceride levels: Intervention 156 to 126, Control 155 to 156, p = .002 between groups
Fletcher, Dunbar, Felner, et al. (1994) United States | Samples size: 92 Gender: 100% men Age: < 73 years, mean 62 years Category: Catheterization-documented CHD (MI, CABG, PTCA). Patients with disability with functional use of two or more extremities, including one arm for exercise testing and training. | Intervention: Home exercise with transtelephonic ECG monitoring. Exercise 20 minutes 5 times/week for 6 months + Step 1 diet (both groups). Intensity not specified. Followup: 6 months | | Mean HDL cholesterol: Intervention 34 to 39 (p = .01), Control 36 to 42 (p = .02) No significant difference between groups. No significant difference between groups in total or LDL cholesterol.

Note: CABG = coronary artery bypass graft surgery; CHD = coronary heart disease; ECG = electrocardiographic; HDL = high-density lipoprotein; LDL = low-density lipoprotein; MI = myocardial infarction; PTCA = percutaneous transluminal coronary angioplasty.

Six of eight randomized controlled trials that reported changes in low-density lipoprotein (LDL) cholesterol levels documented significant lowering of LDL levels in rehabilitation patients compared with control patients. All six involved multifactorial interventions, that is, exercise training and behavioral counseling and/or dietary instruction and counseling DeBusk, Houston Miller, Superko, et al., 1994; Hambrecht, Niebauer, Marburger, et al., 1993; Haskell, Alderman, Fair, et al., 1994; Ornish, Brown, Scherwitz, et al., 1990; Schuler, Hambrecht, Schlierf, et al., 1992b; Watts, Lewis, Brunt, et al., 1992). Two of these trials used lipid-lowering medications in addition to exercise training, education, and behavioral strategies (DeBusk, Houston Miller, Superko, et al., 1994; Haskell, Alderman, Fair, et al., 1994). The intervention program was home-based in three trials (DeBusk, Houston Miller, Superko, et al., 1994; Hambrecht, Niebauer, Marburger, et al., 1993; Haskell, Alderman, Fair, et al., 1994). Two multifactorial cardiac rehabilitation trials reported no significant difference in LDL cholesterol levels in intervention patients compared with control patients Fletcher, Dunbar, Felner, et al., 1994; Nikolaus, Schlierf, Vogel, et al., 1991).

Nine randomized controlled trials reported changes in HDL cholesterol levels. Two documented statistically significant increases in HDL levels favoring intervention versus control patients; both were multifactorial studies Haskell, Alderman, Fair, et al., 1994; Ornish, Scherwitz, Doody, et al., 1983). Seven trials reported no significant differences in HDL cholesterol levels between groups (DeBusk, Houston Miller, Superko, et al., 1994; Engblom, Hietanen, Hamalainen, et al., 1992; Fletcher, Dunbar, Felner, et al., 1994; Hambrecht, Niebauer, Marburger, et al., 1993; Ornish, Brown, Scherwitz, et al., 1990; Schuler, Hambrecht, Schlierf, et al., 1992b; Watts, Lewis, Brunt, et al., 1992). All but one study Engblom, Hietanen, Hamalainen, et al., 1992) were multifactorial.

Twelve randomized controlled trials reported changes in triglyceride levels. Seven documented significantly lower triglyceride levels in rehabilitation versus control patients; five of these were multifactorial studies ( Hamalainen, Lurrila, Kallio, et al., 1989; Haskell, Alderman, Fair, et al., 1994; Nikolaus, Schlierf, Vogel, et al., 1991; Ornish, Scherwitz, Doody, et al., 1983; Watts, Lewis, Brunt, et al., 1992).

In summary, the 18 randomized controlled trials reported changes in lipid and lipoprotein levels (total cholesterol, LDL cholesterol, HDL cholesterol, and triglycerides) as a result of rehabilitation services, including exercise training. Favorable outcomes included significant reductions in total cholesterol, LDL cholesterol, and triglyceride levels and significant increases in HDL cholesterol levels. The 18 trials reported 46 comparisons: 26 were significant favorable changes, and 20 showed no significant differences between intervention and control groups. Of the 26 favorable lipid outcomes, 22 resulted from multifactorial rehabilitation, that is, dietary and behavioral strategies in addition to exercise training and, in some studies, the use of lipid-altering medications. Among the 20 lipid comparisons that showed no differences between rehabilitation and control patients, 13 came from multifactorial interventions (Figure 3). Thus, favorable changes in lipid levels are more likely to result from multifactorial cardiac rehabilitation. Most of these randomized controlled trials involved patients following myocardial infarction (nine studies), with varied presentations of coronary disease (eight studies), or following CABG (three studies).

3. Changes in lipid levels in 18 randomized controlled trials of cardiac rehabilitation by intervention strategy—exercise only versus multifactorial intervention

Six nonrandomized controlled studies reported changes in lipid levels following exercise rehabilitation. One study did not report sufficient lipid data for evaluation ( Hedback and Perk, 1987), and three of the remaining five studies reported statistically significant beneficial lipid changes favoring rehabilitation versus nonrandomized control patients Ben-Ari, Rothbaum, Linnemeir, et al., 1989; Blumenthal, Emery, and Rejeski, 1988; Dressendorfer, Smith, Hollingsworth, et al., 1990). One additional trial reported significant increases in mean HDL cholesterol levels following 6 months of exercise rehabilitation (Milani, Littman, and Lavie, 1993). Eight of the 13 observational reports favorable changes in lipid levels after exercise training, with and without other rehabilitation interventions Cowan, 1983; Ferguson, Petitclerc, Choquette, et al., 1974; Heath, Ehsani, Hagberg, et al., 1983; Lavie, Milani, and Littman, 1993; Monpere, Francois, Brochier, et al., 1988; Roviaro, Holmes, and Holmsten, 1984; Smith, Layton, Newmark, et al., 1987; Streja and Mymin, 1979); five reports indicated no significant improvement in lipid levels ( Cannistra, Balady, O'Malley, et al., 1992; Hands, Briffa, Henderson, et al., 1987; Kinsey, Fletcher, Rice, et al., 1989; Superko, 1983; Wrisley and Rubenfire, 1988).

### Conclusions

Improvement in lipid profiles resulting from multifactorial cardiac rehabilitation is well established by review of the scientific literature. Most randomized controlled trials reported beneficial effects on total cholesterol, LDL cholesterol, HDL cholesterol, and triglyceride levels favoring rehabilitation versus control patients. Well-designed nonrandomized controlled trials reported similar beneficial outcomes. The rehabilitation studies that reported the most favorable impact on lipid levels were multifactorial, that is, providing exercise training, dietary education and counseling, and, in some studies, pharmacologic treatment, psychological support, and behavioral training. The specific effects of exercise training alone on lipid changes could not be isolated with a multifactorial rehabilitation study design. These favorable effects on lipid profiles involved patients who were both younger and older than 65 years of age. Although a small proportion (10-22 percent) of women participated in some studies, no study reported lipid outcomes by gender. Furthermore, no study reported lipid outcomes by age. In addition, the confounding variable of concomitant weight loss was not analyzed and could have an independent influence on lipid changes.

The panel concurs with the recommendation of The Second Report of the Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel II) (NCEP II) regarding the role of physical activity for lipid control, namely "the appropriate use of physical activity is considered an essential element in the nonpharmacologic therapy of elevated serum cholesterol" (National Cholesterol Education Program, 1993).

The panel also noted the results of a major randomized placebo-controlled trial of cholesterol lowering in 4,444 patients with CHD, 80 percent with prior myocardial infarction. Patients who were treated with a cholesterol-altering medication showed a significant reduction in total mortality (p = .0003), coronary death, and major coronary events (p < .00001) compared with placebo-treated patients. No difference in noncardiovascular mortality was documented. Favorable results occurred in patients who were both younger and older than 60 years of age and in both men and women. The panel agrees with the trial conclusions that patients with coronary disease and diet-resistant cholesterol levels above 210 mg/dL should be considered for treatment with lipid-altering medication (Scandinavian Simvastatin Survival Study Group, 1994).

## Body Weight

RECOMMENDATION: Cardiac rehabilitation exercise training as a sole intervention has an inconsistent effect on controlling overweight and is not recommended as a sole intervention for this risk factor. Optimal management of overweight requires multifactorial rehabilitation including nutritional education and counseling and behavioral modification in addition to exercise training.

### Scientific Evidence (Strength of Evidence = C)

The scientific evidence pertaining to the effect of exercise training on body weight included 34 scientific reports. Eleven of these studies were randomized controlled trials, 7 were nonrandomized controlled studies, and 16 were observational reports.

Two of the 10 randomized controlled trials involved exercise training as the sole intervention. One documented favorable reduction in body weight in intervention versus control patients (Wilhelmsen, Sanne, Elmfeldt, et al., 1975), and the other showed no significant difference Carson, Phillips, Lloyd, et al., 1982). One study compared exercise training with exercise training plus education/counseling with a control group and documented no significant difference between the three groups in weight loss at the 3- and 6-month followups (Sivarajan, Newton, Almes, et al., 1983). Seven randomized controlled trials were multifactorial and included nutritional education and counseling, as well as behavioral modification; five reported changes in body weight, with two documenting a favorable outcome in intervention patients compared with control patients ( Kallio, Hamalainen, Hakkila, et al., 1979; Ornish, Brown, Scherwitz, et al., 1990) and three reporting no significant difference (Bengtsson, 1983; Engblom, Ronnemaa, Hamalainen, et al., 1992; Vermeulen, Lie, and Durrer, 1983). Body mass index was addressed in three randomized controlled trials, with all documenting significant improvement favoring rehabilitation versus control patients Hambrecht, Niebauer, Marburger, et al., 1993; Haskell, Alderman, Fair, et al., 1994; Schuler, Hambrecht, Schlierf, et al., 1992b); one also reported significant improvement by skin-fold measurements ( Haskell, Alderman, Fair, et al., 1994).

No randomized controlled trial reported results separately by age of patients or by gender. Stratification by degree to which patients were overweight or by adiposity at baseline related to changes in measures of body weight or percentage of body fat was not carried out.

The randomized controlled trials that documented favorable weight reduction in intervention versus control patients identified this outcome after relatively long followups of 4 years Wilhelmsen, Sanne, Elmfeldt, et al., 1975), 2 years (Kallio, Hamalainen, Hakkila, et al., 1979), and 1 year ( Ornish, Brown, Scherwitz, et al., 1990).

Two of the seven nonrandomized controlled studies were multifactorial; both showed no difference between groups regarding changes in body weight (Ben-Ari, Kellermann, Fisman, et al., 1986; Ben-Ari, Rothbaum, Linnemeir, et al., 1989). The remaining five nonrandomized controlled trials involved exercise training as the sole intervention. Two reported a favorable effect on body weight, body mass index, and lean body mass for exercise versus control patients (Kavanagh, Yacoub, Mertens, et al., 1988; Stuart, Koyal, Lundstrom, et al., 1985). The other three reported no significant differences between groups in body weight, body mass index, or skin-fold measurements (Ades and Grunvald, 1990; Milani, Littman, and Lavie, 1993; Stewart, Mason, and Kelemen, 1988).

Eight of the 16 observational studies of exercise-based rehabilitation reported significant reduction in measures of body weight or body mass index (Ades, Waldmann, Poehlman, et al., 1993; Braun, Parcels, Brooks, et al., 1989; Ehsani, Martin, Heath, et al., 1982; Ferguson, Petitclerc, Choquette, et al., 1974; Kinsey, Fletcher, Rice, et al., 1989; Lavie, Milani, and Littman, 1993; Monpere, Francois, Brochier, et al., 1988; Smith, Layton, Newmark, et al., 1987) . Eight of the observational studies reported no significant change (Cannistra, Balady, O'Malley, et al., 1992; Cardus, McTaggart, and Ribas-Cardus, 1980; Heath, Ehsani, Hagberg, et al., 1983; Kavanagh, Yacoub, Mertens, et al., 1988; Roviaro, Holmes, and Holmsten, 1984; Streja and Mymin, 1979; Superko, 1983; Williams, Maresh, Esterbrooks, et al., 1985).

### Conclusions

Rehabilitative exercise training, when a component of multifactorial intervention, appears to have a beneficial effect in improving body weight or other measures of excess body mass or percentage of body fat. Exercise training as a sole intervention has no consistent effect. No exercise-training study specifically targeted overweight coronary patients, and delineation of what constituted being "overweight" varied among studies. There is a clear need to scientifically evaluate the role of multifactorial cardiac rehabilitation in effecting desired weight change in overweight patients with coronary disease. Also, it is recognized that sustained weight loss has been a difficult goal to achieve in a number of different clinical and population studies.

Approximately half of the studies dealt only with male patients, and studies that included women had a small proportion of women patients (12-20 percent). The sole study that reported outcomes by gender showed no significant difference between men and women in improvement in the percentage of body fat Cannistra, Balady, O'Malley, et al., 1992). No study presented outcomes based on the degree of patients' overweight or obesity at baseline. These studies principally involved patients who were younger than 65 years of age, with the mean age predominately in the 50s. One nonrandomized controlled trial reported favorable changes in body mass index in patients both younger and older than 65 years of age Lavie, Milani, and Littman, 1993).

## Blood Pressure

RECOMMENDATION: Rehabilitative exercise training as a sole intervention has no demonstrable effect in lowering blood pressure levels. Multifactorial cardiac rehabilitation, including exercise training, has an inconsistent effect in lowering blood pressure levels; major confounding variables include the use of antihypertensive medication and medication changes.

### Scientific Evidence (Strength of Evidence = B)

The scientific data that address the effect of exercise training, with and without other cardiac rehabilitation services, on blood pressure levels include 18 studies: 9 randomized controlled trials, 6 nonrandomized controlled studies, and 3 observational reports.

Three of the nine randomized controlled trials involved patients after myocardial infarction and reported a favorable effect of rehabilitative exercise training versus control status on mean blood pressure levels, with an average blood pressure reduction of 7 mmHg systolic and 4 mmHg diastolic ( Hamalainen, Luurila, Kallio, et al., 1989; Kallio, Hamalainen, Hakkila, et al., 1979; Wilhelmsen, Sanne, Elmfeldt, et al., 1975); all three studies were multifactorial. Five randomized controlled trials reported no significant difference in blood pressure levels between exercise and control patients; three were multifactorial Engblom, Ronnemaa, Hamalainen, et al., 1992; Ornish, Brown, Scherwitz, et al., 1990; Plavsic, Turkulin, Perman, et al., 1976), and two involved only exercise training Coats, Adamopoulos, Meyer, et al., 1990; Vermeulen, Lie, and Durrer, 1983). One multifactorial study reported significant lowering of systolic blood pressure levels in intervention patients compared with control patients (Haskell, Alderman, Fair, et al., 1994).

Five of the six nonrandomized controlled studies reported a statistically significant greater reduction in blood pressure in rehabilitation patients versus control patients; these included four multifactorial studies (Ben-Ari, Kellermann, Fisman, et al., 1986; Hedback and Perk, 1987; Hedback, Perk, and Engvall, 1992; Hedback, Perk, Engvall, et al., 1990) and one exercise-only trial Kavanagh, Yacoub, Mertens, et al., 1988). One multifactorial study reported no difference Perk, Hedback, and Jutterdal, 1989). When sufficient data were available, average reductions in systolic and diastolic blood pressures between intervention and control groups were 13 and 10 mmHg, respectively (Hedback, Perk, and Engvall, 1992; Kallio, Hamalainen, Hakkila, et al., 1979).

One observational study reported improved home-monitored blood pressure control following rehabilitation Kinsey, Fletcher, Rice, et al., 1989), and two did not (Roviaro, Holmes, and Holmsten, 1984; Williams, Maresh, Esterbrooks, et al., 1985).

Detailed information regarding potential confounding variables such as concomitant changes in body weight, percentage of body fat, habitual physical activity, dietary habits, and particularly the percentage of patients taking antihypertensive medications (as well as adherence to antihypertensive medications) was often lacking, thereby limiting the value of the results. Patients with elevated baseline blood pressure levels generally showed the greatest reductions in blood pressure with exercise training. Many coronary patients were normotensive or mildly hypertensive at baseline.

### Conclusions

Review of the scientific evidence suggests that exercise-based cardiac rehabilitation has only modest effects in reducing blood pressure levels. The generalizability of these data is limited by the small numbers of women who were enrolled in these studies. Of major importance is that no study was specifically designed to address hypertension control in patients with elevated blood pressures participating in exercise-based cardiac rehabilitation. The confounding effects on blood pressure change of weight reduction, dietary habits, and antihypertensive medications was not addressed in any of the studies. It is unlikely that hypertensive patients with coronary disease would be provided solely exercise training without other appropriate therapies such as weight reduction, sodium restriction, moderation or abstinence from alcohol, or pharmacologic therapy, although these components may have been directed by the patient's treating physician. The panel supports the recommendations of The Fifth Report of the Joint National Committee on Detection, Evaluation and Treatment of High Blood Pressure (JNC V), advising physical activity as a nonpharmacologic approach to the control of elevated blood pressure (National High Blood Pressure Education Program, 1993).

Most exercise-based cardiac rehabilitation studies that reported blood pressure changes were conducted in relatively young patients, generally younger than 65 years of age. Only two studies included elderly patients (Haskell, Alderman, Fair, et al., 1994; Williams, Maresh, Esterbrooks, et al., 1985). The effect of exercise rehabilitation on elderly patients with elevated blood pressures has not been well defined. Furthermore, the more intensive use of pharmacologic therapies to control elevated blood pressure levels in contemporary cardiovascular care may render the information from older trials less meaningful.

## Psychological Well-Being

RECOMMENDATION: Cardiac rehabilitation exercise training -- with and without other cardiac rehabilitation services -- generally results in improvement in measures of psychological status and functioning. Exercise training as a sole intervention does not consistently result in improvement in measures of anxiety and depression. Exercise training is recommended to enhance measures of psychological functioning, particularly as a component of multifactorial cardiac rehabilitation.

### Scientific Evidence (Strength of Evidence = B)

Nineteen scientific studies reported a variety of measures of psychological status or functioning before and after exercise-based cardiac rehabilitation. Nine were randomized controlled trials, eight were nonrandomized controlled studies, and two were observational studies. The randomized and nonrandomized controlled trials that reported measures of psychological outcomes are presented in Tables 5 and 6.

Table 5. Effect of exercise training plus other cardiac rehabilitation services on psychological parameters: Randomized controlled trials

Reference, Country | Patients | Intervention, Followup | | Outcome
Bengtsson (1983) Sweden | Sample size: 87 Gender: 80% men Age: 39-65 years Category: MI | Intervention: Supervised aerobic exercise. 90% maximal exercise test heart rate intensity. Individual and family counseling for 3 months. Followup: 14 months | | MMPI: No significant differences between groups
Stern, Gorman, and Kaslow (1983) United States | Sample size: 106 Gender: 86% men Age: 30-69 years Category: MI | Intervention: Supervised aerobic exercise, 85% maximal intensity heart rate and group counseling for 12 weeks Followup: 3 months, 6 months and 1 year | | At 3 months, significant improvement group counseling vs. control (p < .05) in depression, fatigue, friendliness, social and functional adjustment At 6 months, no significant difference exercise vs. control. Significant improvement group counseling vs. control in anxiety (p < .05), depression (p < .03), friendliness (p < . 009), and marital dependency (p < .04) At 12 months, significant improvement in exercise and group counseling vs. control only in scale for marital dependency (p < .05)
Ott, Sivarajan, Newton, et al. (1983) United States | Sample size: 258 (88 exercise, 86 exercise plus education/counseling, 84 control) Gender: 80% men Age: 70 years and younger, mean 56-57 years Category: Uncomplicated MI | Setting: Home and rehabilitation center Intervention: Supervised weekly group exercise for 30 minutes. Intensity not specified. 3-month duration both groups + education/counseling. Eight 1-hour group sessions weekly. Followup: 3 and 6 months | | Measures of dysfunctional behavior showed significant improvement with exercise + education/ counseling group vs. exercise-only or control groups at 3 and 6 months (p < .05) Exercise + education/ counseling group showed significant improvement compared with control in measures of social interaction at 3 (p < .05) and 6 months (p < .01)
Taylor, Houston-Miller, Ahn, et al. (1986) United States | Sample size: 210 Gender: 100% men Age: < 70 years Category: 3 weeks after uncomplicated MI. Anxiety and depression levels normal at baseline. | Intervention: Home vs. gymnasium exercise vs. no exercise control for 26 weeks. Similar intensity, but no specifics provided. Followup: 26 weeks | | Hamilton Depression Index: Improved significantly gymnasium vs. no exercise (p < .01) State and trait anxiety: All groups showed reduction, gymnasium group significant reduction vs. no-exercise control group (p < .01). No change in marital satisfaction rating among groups. Psychological adjustment: No change among groups. Change in depression and anxiety significantly correlated with change in treadmill exercise performance.
Erdman, Duivenvoorden, Verhage, et al. (1986) The Netherlands | Sample size: 57 Gender: 100% men Age: 35-60 years Category: MI | Intervention: Supervised gymnasium vs. home exercise for 6 months Followup: 6 months and 5 years | | No significant difference in measures of well-being, feelings of disability, despondency, or social inhibition at 6 months or 5 years.
Newton, Mutrie, and McCarthur (1991) United Kingdom | Sample size: 22 Gender: Men and women, percentage not specified Age: < 70 years Category: MI | Intervention: Exercise rehabilitation, 3 times/week, 30 minutes/session for 10 weeks. Followup: 16 weeks | | Depression, anger, and tension scores significantly diminished in exercise group (p < .03) Mood disturbance score, vigor and confusion score, no significant changes. Fatigue scores significantly higher in both groups. p values not provided.
Gulanick (1991) United States | Sample size: 36 Gender: 70% men Age: Mean 57 years Category: Catheterization-documented CHD | Intervention: Exercise testing + teaching and exercise training (n = 11) with exercise training 3 times/week for 5 weeks. Exercise testing and teaching only (n = 15) or control without exercise testing, teaching or exercise training (n = 14). Followup: 4 and 9 weeks | | Measures of self-efficacy increased significantly over time in all groups (p < .001) No significant difference between groups
Oldridge, Guyatt, Jones, et al. (1991) United States | Sample size: 201 (99 rehabilitation, 102 conventional care) Gender: 88% men Age: Mean 53 years Category: MI | Intervention: Supervised exercise 65% maximal baseline exercise test heart rate and behavioral counseling for 8 weeks Followup: 8 weeks and 12 months | | Health-related quality of life improved significantly in both groups (p < .001). No significant difference between groups. Emotions improved significantly in treatment group at 8 weeks only (p < .05) Depression scores not significantly different between groups at any time
Worcester, Hare, Oliver, et al. (1993) Australia | Sample size: 224 (108 high-intensity training, 116 low- intensity training) Gender: 100% men Age: Mean 54 years Category: MI | Intervention: Exercise training 30 minutes at 70-85% maximal baseline heart rate 3 times/week for 8 weeks. Light exercise: Limited activity in classes 2 times/week for 8 weeks. Both groups encouraged to walk daily at home. Followup: 4 and 12 months | | No significant differences between groups in any measure of psychological functioning or quality of life Significantly greater mean improvement in score of occupational adjustment over time in higher intensity group (p < .025) No significant difference between groups at 12-month followup

Note: CHD = coronary heart disease; MI = myocardial infarction; MMPI = Minnesota Multiphasic Personality Inventory.

Table 6. Effect of exercise training plus other cardiac rehabilitation services on psychosocial parameters: Nonrandomized controlled trials

Reference, Country | Patients | Intervention, Followup | | Outcome
Naughton, Bruhn, and Lategola (1968) United States | Sample size: 42 Gender: 100% men Age: Not specified Category: MI and healthy controls | Intervention: Calisthenics, competitive games. Daily walking and jogging. Duration not specified. Followup: 6 months | | Exercise patients showed diminished depression and hypochondriasis (MMPI) but no statistically significant difference between groups
Raineri, Assennato, Candela, et al. (1982) Italy | Sample size: 106 Gender: 100% men Age: < 65 years Category: MI | Intervention: Calisthenics, walking, jogging, and cycle ergometry for 4 months Followup: 2 years | | Trend toward normalization of anxiety levels exercise group only. No p values provided.
Roviaro, Holmes, and Holmsten (1984) United States | Sample size: 48 Gender: 100% men Age: 27-69 years Category: MI, CABG | Intervention: Walking, jogging, cycling, swimming. Intensity not provided; duration 3 months. Followup: 4 months after program completion | | Body-concept perceptions: Significant difference in exercise vs. control (p < .05 for all concepts) Tennessee Self-Concept scale: Significant increase, exercise vs. control (p = .02) Beck Depression Inventory: Exercise vs. control significantly better mood scores, less indecisiveness, less fatigue (p < .05 for all scores). Significant improvement exercise vs. control in measures of irritability and guilt (p < .05).
Ben-Ari, Kellermann, Fisman, et al. (1986) United States | Sample size: 51 Gender: Not specified Age: Mean 52.5 years Category: CABG | Intervention: Cycle ergometry initially 50%, increasing to 85% of age-predicted maximal heart rate for "long term" Followup: 1 year and 4.8 years | | 1 year: "Good quality of life" reported 73% of exercise vs. 45% control (p < .001) 4.8 years: 55% exercise vs. 25% control (p < .001).
Stewart, Mason, and Kelemen (1988) United States | Sample size: 25 Gender: 100% men Age: < 70 years, mean 58 years Category: Catheterization-documented CHD | Intervention: Aerobic-only exercise vs. aerobic exercise + circuit weight training for 3 years Followup: 3 years | | Self-efficacy for arm use significantly increased in circuit weight training group vs. baseline and vs. aerobic-only training group (p < .05) Leg use self-efficacy scores not significantly different in either group (p < .11)
Hertzeanu, Shemesh, Aron, et al. (1993) Israel | Sample size: 38 Gender: Not specified Age: Mean 61 years Category: MI. Mean left ventricular ejection fraction < 40%. | Intervention: Arm training group vs. calisthenics group. 60 months arm training, 36 months calisthenics. Followup: 60 months arm training, 36 months calisthenics | | Fear and anxiety: Expressed by 0% of arm group, 13% of calisthenic group, and 33% of control (no p value provided) Work activity: 46% of arm training group, 73% of calisthenics group, and 13% control
Denollet (1993a) Belgium | Sample size: 120 (60 intervention, 60 control) Gender: 100% men Age: Mean 56 years Category: CHD. 30 patients each group had baseline high distress or low distress on Despondency scale of Heart Patient's Psychological Questionnaire. | Intervention: Multifactorial. Cycle ergometry exercise, treadmill exercise and psychological intervention for 3 months. Followup: 3 months | | No significant change in control patients in disability scores or scores in Heart Patient's Psychological Questionnaire Significant reduction in disability scores (p < .001 intervention vs. control) Well-being score significantly increased in intervention patients (p < .001 intervention vs. control) Less tranquilizer use intervention vs. control patients (22% vs. 42%, p < .05)
Denollet (1993b) Belgium | Sample size: 120 (60 intervention, 60 control) Gender: 100% men Age: Mean 56 years Category: CHD. All patients completed 20-item Global Mood Scale at baseline and followup. | Intervention: Multifactorial. Cycle and treadmill exercise with ECG monitoring. Ball games and cycle exercise without ECG monitoring, and psychological group counseling with spouse for 3 months. Followup: 3 months | | Negative affect scores reduced significantly in intervention patients vs. no significant change in controls (p < .0001 between groups) Positive affect scores increased significantly in intervention patients compared with controls (p < .0001 between groups)

Note: CABG = coronary artery bypass graft surgery; CHD = coronary heart disease; ECG = electrocardiographic; MI = myocardial infarction; MMPI = Minnesota Multiphasic Personality Inventory.

Three of the nine randomized controlled trials involved only exercise training. Two of these three reported statistically significant improvement in various measures of psychological functioning favoring rehabilitation patients versus control patients (Newton, Mutrie, and McCarthur, 1991; Taylor, Houston-Miller, Ahn, et al., 1986). The other exercise-only trial reported no statistically significant difference between groups Erdman, Duivenvoorden, Verhage, et al., 1986). One randomized controlled trial compared exercise versus exercise plus education/counseling versus control status in patients after myocardial infarction and evaluated changes in the Sickness Impact Profile at 3- and 6-month followups (Ott, Sivarajan, Newton, et al., 1983). The measures of dysfunctional behavior showed significant improvement in the exercise plus education/counseling group versus exercise-only or control groups at both 3 and 6 months. The exercise plus education/counseling group showed significant improvement compared with control patients in measures of social interaction at 3 and 6 months.

Four additional randomized controlled trials involved multifactorial interventions. Three showed significant improvement in psychological variables in the rehabilitation patients Gulanick, 1991; Oldridge, Guyatt, Jones, et al., 1991; Stern, Gorman, and Kaslow, 1983), and one showed significant improvement in measures of quality of life (Oldridge, Guyatt, Jones, et al., 1991). One multifactorial randomized controlled trial reported no difference between groups Bengtsson, 1983). An additional randomized controlled trial compared high-intensity with light-intensity exercise training in men after myocardial infarction and reported no significant differences between groups in any measure of psychological functioning or quality of life at the 4- and 12-month followups. Significantly greater mean improvement in the score of occupational adjustment occurred in the high-intensity group, but there was no significant difference between groups at the 12-month followup (Worcester, Hare, Oliver, et al., 1993).

Five of the eight nonrandomized controlled studies reported statistically significant beneficial outcomes favoring intervention patients versus control patients. Three of these five involved exercise training as the sole intervention ( Ben-Ari, Kellermann, Fisman, et al., 1986; Roviaro, Holmes, and Holmsten, 1984; Stewart, Mason, and Kelemen, 1988), and two studies were multifactorial (Denollet, 1993a; Denollet, 1993b). (One report described two separate studies, one observational and one nonrandomized controlled.) The three other nonrandomized studies did not report any tests of statistical significance for their results Hertzeanu, Shemesh, Aron, et al., 1993; Naughton, Bruhn, and Lategola, 1968; Raineri, Assennato, Candela, et al., 1982).

Two observational studies reported improvement in psychological measures following rehabilitation (Denollet, 1993a; Stern and Cleary, 1981).

In summary, 13 of 17 randomized and nonrandomized controlled studies documented statistically significant improvement in measures of psychological status favoring rehabilitation versus control patients, including 7 of 9 exercise-only studies and 4 of 6 multifactorial studies. No study documented worsening of measures of psychological status comparing rehabilitation with control patients.

### Conclusions

Cardiac rehabilitation exercise training, either alone or as a component of multifactorial rehabilitation, often results in improvement in various measures of psychological status and functioning. This evidence from the scientific literature is consistent with the widespread belief among cardiac rehabilitation professionals that cardiac rehabilitation exercise training improves the sense of well-being among participants. The evidence particularly supports improvement among individuals with high levels of distress at the time of entry into the study. The instruments used to measure psychological outcomes differed widely and are those often designed to measure abnormal responses and changes in patients with psychological or psychiatric illness; even with use of these instruments, improvement in psychological status was documented in patients not specifically targeted because of psychological illness. Patients tended to perceive themselves as improving in a number of psychosocial domains, although these perceptions may not have been objectively documented. More sensitive tests may have to be developed to better ascertain changes in cardiac patients without specific psychiatric illness, and those data are very limited for elderly patients.

Studies of exercise rehabilitation as the sole intervention are confounded by the consequences of group interaction, formation of social support networks, peer and professional support, counseling and guidance, all of which may affect depression, anxiety, and self-confidence.

## Social Adjustment and Functioning

RECOMMENDATION: Cardiac rehabilitation exercise training improves social adjustment and functioning. Exercise training is recommended to improve these social outcomes.

### Scientific Evidence (Strength of Evidence = B)

Six reports in the scientific literature addressed various measures of social adjustment and functioning in patients following cardiac rehabilitation exercise training. These measures include the Sickness Impact Profile scores, leisure and social questionnaire scores, social activity scores, and scores of satisfaction with work and social satisfaction. Two studies were randomized controlled trials, one was a nonrandomized controlled study, and three were observational reports.

Both randomized controlled trials reported favorable outcomes in rehabilitation patients compared with control patients Bar, Hoppener, Diederiks, et al., 1992; Ott, Sivarajan, Newton, et al., 1983). In one trial, the benefit was noted at the 3-month followup but not at the 6-month followup (Ott, Sivarajan, Newton, et al., 1983). The second randomized controlled trial documented benefit at the 1-year followup ( Bar, Hoppener, Diederiks, et al., 1992).

The nonrandomized controlled study did not report statistically significant improvements in measures of social and work satisfaction in patients with diminished left ventricular ejection fraction (less than 40 percent) but no symptoms of heart failure (Hertzeanu, Shemesh, Aron, et al., 1993).

One observational study of 3 months of exercise training as the sole intervention in patients following myocardial infarction or CABG reported improvement in social functioning at 4 months Hartung and Rangel, 1981). Two additional observational studies reported improvement in social functioning following cardiac rehabilitation exercise training Myrtek, 1987; Stern and Cleary, 1981).

### Conclusions

The social benefits, established by randomized controlled trials, are a favorable result of participation in exercise and multifactorial cardiac rehabilitation. Only two reports, and only one controlled trial, involved patients over 65 years of age, for whom social outcomes may differ from those in most of the patients studied, who were younger than age 60-65. Only two controlled trials included women, and in these, women were 15 and 17 percent of the patients; no social outcomes were reported by gender. Only one controlled trial involved multifactorial rehabilitation; all others reported social outcomes associated with exercise training as the sole intervention.

More research is needed to evaluate various measures of social adjustment or functioning as an outcome of multifactorial cardiac rehabilitation.

## Return to Work

RECOMMENDATION: Cardiac rehabilitation exercise training exerts less influence on rates of return to work than many nonexercise variables including employer attitudes, prior employment status, economic incentives, and the like. Exercise training as a sole intervention is not recommended to facilitate return to work.

### Scientific Evidence (Strength of Evidence = A)

The scientific evidence relating to return to work as an outcome of exercise-based cardiac rehabilitation was derived from 28 reports. Ten were randomized controlled trials, nine were nonrandomized controlled studies, and nine were observational reports. One study evaluated the effect of exercise testing and physician counseling following uncomplicated myocardial infarction on return to work.

Higher rates of return to work were evident in 2 of the 10 randomized controlled trials, both of which were carried out in Europe, where the social structure of rehabilitation may greatly differ from that in the United States ( Lamm, Denolin, Dorossiev, et al., 1982; Schiller and Baker, 1976); increased maintenance of work at 6 months was also noted in one of these studies ( Schiller and Baker, 1976). Eight randomized controlled trials documented no difference in rates of return to work for rehabilitation patients compared with control patients Bar, Hoppener, Diederiks, et al., 1992; Bengtsson, 1983; Carson, Phillips, Lloyd, et al., 1982; DeBusk, Houston, Haskell, et al., 1979; Erdman, Duivenvoorden, Verhage, et al., 1986; Marra, Paolillo, Spadaccini, et al., 1985; Mayou, MacMahon, Sleight, et al., 1981; Oldridge, 1991). No study demonstrated an adverse effect of exercise rehabilitation on return to work. One randomized controlled trial reported the value of exercise testing followed by physician counseling based on exercise test results on return to work after myocardial infarction: A statistically significant earlier return to work, in both manual and nonmanual workers, occurred in counseled patients compared with control patients Dennis, Houston-Miller, Schwartz, et al., 1988).

Seven of the nine nonrandomized controlled studies reported a significantly greater return to work, with higher rates reported exercise rehabilitation populations than in control populations (Ben-Ari, Kellermann, Fisman, et al., 1986; Ben-Ari, Rothbaum, Linnemeier, et al., 1992; Gutmann, Knapp, Pollock, et al., 1982; Hedback and Perk, 1987; Hedback, Perk, and Wodlin, 1993; Hertzeanu, Shemesh, Aron, et al., 1993; Levin, Perk, and Hedback, 1991). Eight of the nine observational studies reported a favorable effect of exercise rehabilitation on work resumption ( Boulay, David, and Bourassa, 1982; Fioretti, Baardman, Deckers, et al., 1988; Kellermann, Shemesh, Fisman, et al., 1990; Monpere, Francois, Brochier, et al., 1988; Myrtek, 1987; Niset, Coustry-Degre, and Degre, 1988; Stern and Cleary, 1981; Waites, Watt, and Fletcher, 1983). One report of the effects of lower versus higher levels of exercise training on rates of return to work found no differences between the two exercise-training regimens (Worcester, Hare, Oliver, et al., 1993).

Virtually all patients studied were younger than 65 years of age, with the mean age often between 50 and 59. Women were infrequently represented, accounting for 12-25 percent of the study populations when enrolled; no return to work data were provided by gender. These features limit the generalizability of results.

The results did not appear to differ in populations of patients with myocardial infarction, CABG, or PTCA. Both studies of patients with a decreased left ventricular ejection fraction Hertzeanu, Shemesh, Aron, et al., 1993; Kellermann, Shemesh, Fisman, et al., 1990) described a favorable return to work, as did the observational report of patients after cardiac transplantation Niset, Coustry-Degre, and Degre, 1988).

One randomized controlled trial ( Schiller and Baker, 1976) defined predictors of failure to return to work as being unemployed at the time of infarction, an unstable work history, the patient's opinion that the job would not be available at recovery, family and social instability, later age of having started smoking, high anxiety and depression scores on the MMPI, lower educational level, and unskilled prior occupation. One randomized controlled trial (Bar, Hoppener, Diederiks, et al., 1992) defined baseline anxiety as a significant negative influence on return to work, as well as older age, dyspnea at myocardial infarction, and low leisure and social activity scores at baseline. In another randomized controlled trial (Hedback, Perk, and Wodlin, 1993 ), low-risk status following infarction was associated with an earlier return to work than was high-risk status. In a nonrandomized controlled trial (Hedback, Perk, and Engvall, 1992), older age and prior myocardial infarction resulted in a decreased return to work, as did cigarette smoking, hypertension, and extended sick leave prior to CABG. In observational studies, higher life-satisfaction scores (Myrtek, 1987) predicted increase in return to work, and lower baseline functional capacity (Fioretti, Baardman, Deckers, et al., 1988) predicted failure to resume work. No study examined the relationships among rehabilitation exercise training, the type of work or physical demands of employment, and the rate of return to work. No study identified specific vocational interventions.

### Conclusions

Assessment of return to work as a result of exercise training must be considered within the context of social and political variables that are typically not addressed in the studies of cardiac rehabilitation. These variables include the political system and social policies of the country in which cardiac rehabilitation occurs. Additional factors include employment statistics for the years of the study for U.S. studies, economic incentives or disincentives for patients to return to work, non-patient-related factors such as employer attitudes, and the preillness employment status of the patient, among others. A number of studies failed to compare outcomes in patients employed or not employed at the time of the cardiac event and often, for unemployed patients, did not define the duration of preillness or prerehabilitation unemployment -- variables known to influence return to work. Generalizability may further be limited in that patients who are study volunteers may be more likely to return to work. Finally, return to work as a measure of outcome of exercise-based cardiac rehabilitation may not be appropriate unless formal vocational rehabilitation services are provided to patients as part of the rehabilitative process.

## Morbidity and Safety Issues

RECOMMENDATION: Cardiac rehabilitation exercise training does not change the rates of nonfatal reinfarction. The safety of exercise rehabilitation is well established; rates of infarction and cardiovascular complications during exercise training are very low.

### Scientific Evidence (Strength of Evidence = A)

Evidence pertaining to cardiovascular morbidity related to exercise rehabilitation was derived from 42 scientific reports, including 15 randomized controlled trials, 14 nonrandomized controlled studies, and 13 observational reports. In addition, two large questionnaire surveys of cardiac rehabilitation programs, which specifically assessed morbidity rates, were included in the review.

All 15 randomized controlled trials, including 10 involving only exercise training and 5 multifactorial studies, reported no statistically significant differences in the rates of reinfarction for rehabilitation and control patients Bengtsson, 1983; Carson, Phillips, Lloyd, et al., 1982; Erdman, Duivenvoorden, Verhage, et al., 1986; Hamalainen, Luurila, Kallio, et al., 1989; Haskell, Alderman, Fair, et al., 1994; Hung, Gordon, Houston, et al., 1984; Kallio, Hamalainen, Hakkila, et al., 1979; Kentala, 1972; Marra, Paolillo, Spadaccini, et al., 1985; P.R.E. Cor Group, 1991; Rechnitzer, Cunningham, Andrew, et al., 1983; Roman, Gutierrez, Luksic, et al., 1983; Vermeulen, Lie, and Durrer, 1983; Wilhelmsen, Sanne, Elmfeldt, et al., 1975; Worcester, Hare, Oliver, et al., 1993). These studies are described in Table 7.

Table 7. Morbidity in randomized controlled trials of exercise-based cardiac rehabilitation

Reference, Country | Patients | Intervention, Followup | | Outcome
Kentala (1972) Finland | Sample size: 152 (71 intervention, 81 control) Gender: 100% men Age: < 65 years Category: 6-8 weeks after MI | Intervention: Exercise intensity heart rate 10 bpm below exercise test peak at baseline. 3 times/week for 20 minutes. Control group 1 session of consultation each month. Followup: 12 months | | Nonfatal reinfarction: 6 exercise, 4 control No significant difference
Wilhelmsen, Sanne, Elmfeldt, et al. (1975) Sweden | Sample size: 315 (158 intervention, 157 control) Gender: 138 men intervention, 142 men control Age: 57 years or less Category: 3 months after MI | Intervention: Supervised exercise training. 3 sessions/week for 0.5 hour/session at 80% peak baseline heart rate. 9 months duration. Followup: 4 years | | Nonfatal recurrent MI rate: 16% exercise, 18% control No significant difference
Kallio, Hamalainen, Hakkila, et al. (1979) Finland | Sample size: 325 (187 intervention, 138 control) Gender: 150 men intervention, 151 men control Age: < 65 years, mean 54 years Category: 2 weeks following hospital discharge after MI | Intervention: Multifactorial. Cycle ergometry supervised exercise "most intensive" first 3 months. Health education and psychosocial advice intervention group only. Followup: 3 years | | Nonfatal reinfarction rate: 18% exercise, 11% control No significant difference
Carson, Phillips, Lloyd, et al. (1982) United Kingdom | Sample size: 303 (151 intervention, 152 control) Gender: 100% men Age: < 70 years, range 50-67 years Category: 6 weeks following MI. High-risk patients excluded. | Intervention: Supervised gymnasium aerobic exercise 2 times/week for 12 weeks Followup: 2.1 years | | Nonfatal recurrent MI: 8 exercise, 6 control No significant difference
Bengtsson (1983) Sweden | Sample size: 126 (64 intervention, 62 control) Gender: 80% men Age: Mean 56 years Category: MI | Intervention: Multifactorial. Supervised aerobic exercise 30 minutes/session 2 times/week for 3 months at 90% baseline exercise test heart rate. Individual group and family counseling. Followup: 14 months | | Reinfarction: 2 intervention, 4 control No significant difference
Rechnitzer, Cunningham, Andrew, et al. (1983) Canada | Sample size: 761 (390 high-intensity exercise, 371 low-intensity) Gender: 100% men Age: 26-56 years, median 47 years Category: MI | Intervention: High-intensity (65-85% estimated maximal oxygen uptake) or low-intensity (50% or less estimated maximal oxygen uptake). Supervised 2 times/week for mean of 3.3 years. Followup: Mean 3.3 years | | Nonfatal reinfarction: 39 patients in high intensity group, 33 in low-intensity group No significant difference between groups
Vermeulen, Lie, and Durrer (1983) The Netherlands | Sample size: 98 (47 intervention, 51 control) Gender: 100% men Age: 40-55 years Category: 4-6 weeks following MI | Intervention: Multifactorial. Supervised exercise + social and psychological intervention. Followup: 5 years | | Recurrent MI: 4 intervention, 9 control When added to cardiac mortality outcome of 2 intervention and 5 control patients, difference in both outcomes significantly lower in intervention vs. controls (p < .02)
Roman, Gutierrez, Luksic, et al. (1983) Chile | Sample size: 193 (93 intervention, 100 control) Gender: 86 men intervention, 87 men control Age: Mean 56 years intervention, 59 years control (not significantly different) Category: MI | Intervention: Supervised aerobic exercise 30 minutes 3 times/week at 70% maximal baseline exercise test heart rate Followup: Mean 42 months | | Rates of reinfarction, recurrent acute myocardial ischemia, heart failure, and severe arrhythmia, "no significant difference" between groups.
Hung, Houston, et al. (1984) United States | Sample size: 45 (18 intervention, 27 control) Gender: 100% men Age: < 70, mean 55 years Category: Uncomplicated MI | Intervention: Home cycle ergometry with transtelephonic ECG monitoring. 30 minutes/session, 5 times/week for 11 weeks. Intensity 70-85% of maximal baseline exercise test heart rate. Followup: 26 weeks | | Intervention: 1 nonfatal reinfarction, 2 CABG surgery for refractory Control: 1 fatal reinfarction, 1 unstable angina No significant difference between groups
Marra, Paolillo, Spadaccini, et al. (1985) Italy | Sample size: 161 (81 intervention, 80 control) Gender: Not specified Age: 25-65 years Category: MI | Intervention: Supervised aerobic exercise 1 hour for 30 sessions 4 times/week for 8-9 weeks at 80% maximal baseline exercise test heart rate. Control group: Calisthenics and cycling at home. Followup: 4.5 years | | Nonfatal reinfarction: 5 intervention, 9 control CABG surgery: 7 intervention, 9 control Neither difference was statistically significant
Erdman, Duivenvoorden, Verhage, et al. (1986) The Netherlands | Sample size: 80 Gender: 100% men Age: < 65 years Category: < 6 months following MI. Low-risk patients only. | Intervention: 75 minutes supervised gymnasium exercise 2 times/week for 6 months. Intensity not specified. Followup: 5 years | | No significant differences in any cardiac event rates, including reinfarction, between groups
Hamalainen, Luurila, Kallio, et al. (1989) Finland | Sample size: 375 (188 intervention, 187 control) Gender: 301 men, 74 women Age: < 65 years Category: "A few weeks" following MI | Intervention: Multifactorial. Dietary, antismoking, and psychological counseling + exercise "tailored to individual capacity." Followup: 10 years | | Nonfatal reinfarction: 26% intervention, 19% control No significant difference between groups
P.R.E. Cor Group (1991) France | Sample size: 182 (60 intervention, 61 counseling, 61 usual care) Gender: 100% men Age: < 65 years Category: Within 60 days of MI | Intervention: Exercise rehabilitation (RP) 6 weeks, 3 times/week for 25 minutes at 80% maximal heart rate. 1 counseling (CP) session with medical team and 1 examination by cardiologist. Usual care (UC) with referral to family physician/cardiologist. Followup: Not specified | | Nonfatal reinfarction: Exercise rehabilitation (RP) = 7/60, Counseling (CP) = 7/61, Usual care (UC) = 10/61 No significant difference between groups
Worcester, Hare, Oliver, et al. (1993) Australia | Sample size: 224 (108 high-intensity training, 116 low-intensity training) Gender: 100% men Age: Mean 54 years Category: MI | Intervention: Exercise training, 30 minutes 70-85% maximal baseline heart rate 3 times/week for 8 weeks. Light exercise: Limited activity in classes 2 times/week for 8 weeks. Both groups encouraged to walk daily at home. Followup: 4 and 12 months | | Coronary bypass surgery at 12 months: 1 high-intensity exercise group, none light exercise group. No statistical significance reported. Physical disability at 12 months: 2 high-intensity exercise group, 1 light exercise group. No statistical significance provided.
Haskell, Alderman, Fair, et al. (1994) United States | Sample size: 300 (72 of 145 medically treated usual care; 74 of 139 PTCA usual care; 10 of 16 CABG usual care) Gender: 83% men intervention, 92% men usual care Age: < 75 years, mean 57 years Category: Catheterization-documented CHD. Patients with left ventricular ejection fraction < 0.2 excluded. | Intervention: Multifactorial. Nurse- guided nutritional counseling, behavioral treatment for smoking, and lipid-lowering drugs prescribed on individual basis (90% intervention vs. 23% usual care). Individual home exercise prescription. Followup: 4 years | | Nonfatal infarction: 4 intervention, 10 usual care No significant difference between groups When cardiac death is added to reinfarction, CABG, and PTCA: 25 intervention, 44 usual care (p = .07)

Note: bpm = beats per minute; CABG = coronary artery bypass graft surgery; CHD = coronary heart disease; MI = myocardial infarction.

Seven of the 14 nonrandomized controlled studies reported reinfarction rates. Six of these seven studies involved multifactorial rehabilitation, and two of them reported a significant reduction in reinfarction rates in rehabilitation patients compared with control patients (p = .02, Hedback and Perk, 1987; p < .001, Hedback, Perk, and Wodlin, 1993). Reinfarction rates were reduced in myocardial infarction patients younger than 65 years at the 1- to 5-year followups but not at the 6- to 10-year followups. The other four multifactorial nonrandomized controlled studies did not report statistically significant reductions in reinfarction rates (Ben-Ari, Rothbaum, Linnemeir, et al., 1989; Hedback, Perk, Engvall, et al., 1990; Murray, Herrington, Pettus, et al., 1993; Schuler, Hambrecht, Schlierf, et al., 1992a).

One nonrandomized controlled study with exercise training as the sole rehabilitation intervention reported significant reduction in reinfarction rates in exercise patients compared with control patients; these were men, younger than 51 years of age, who began exercise rehabilitation at least 5 months after myocardial infarction (Rechnitzer, Pickard, Paivio, et al., 1972).

Thirteen observational studies reported information regarding morbidity (Crozier Ghilarducci, Holly, and Amsterdam, 1989; Ehsani, Heath, Hagberg, et al., 1981; Fletcher, 1986; Fletcher, Chiaramida, LeMay, et al., 1984; Ignone, Giordano, and Tavazzi, 1988; Inbar, Wallace, Carter, et al., 1990; Lee, Ice, Blessey, et al., 1979; Oldridge, Haskell, and Single, 1981; Sennett, Pollock, Pels, et al., 1987; Shephard, Corey, and Kavanagh, 1981; Sparling, Cantwell, Dolan, et al., 1990; Verani, Hartung, Hoepfel-Harris, et al., 1981; Waites, Watt, and Fletcher, 1983). None of these studies had a comparison or control group, and therefore, no meaningful conclusions could be drawn regarding the impact of exercise rehabilitation on rates of morbidity.

Two meta-analyses of randomized controlled trials of rehabilitation also reported no significant difference in reinfarction rates in rehabilitation patients compared with control patients (O'Connor, Buring, Yusuf, et al., 1989; Oldridge, Guyatt, Fischer, et al., 1988).

No study documented an increased risk of reinfarction or other adverse cardiovascular outcomes for rehabilitation patients compared with control patients in a sizable database of coronary patients. Specifically, the randomized controlled trials included 3,640 patients, and the nonrandomized controlled trials included 938 patients. Followup as long as 10 years was reported Hamalainen, Luurila, Kallio, et al., 1989).

Two major surveys reported rates of cardiovascular events based on questionnaire responses by rehabilitation programs completing the surveys for two separate time periods. The initial survey involved 30 rehabilitation programs in the United States and Canada during 1960-77; a nonfatal cardiac arrest rate of 1/32,593 patient-hours of exercise and a nonfatal myocardial infarction rate of 1/34,600 patient-hours were reported ( Haskell, 1978). A larger survey of 142 U.S. cardiac rehabilitation programs (1980-84) reported a nonfatal myocardial infarction rate of 1/294,000 patient-hours (Van Camp and Peterson, 1986). The results of these surveys establish that a low rate of serious cardiovascular events occurs in exercise-based cardiac rehabilitation. Caution regarding these rates of cardiovascular events is warranted because the data represent an aggregate analysis of information received from cardiac rehabilitation programs that were sent survey questionnaires and that provided data in a retrospective manner. Furthermore, the survey represents data from the 1980s and may not reflect contemporary management of coronary patients.

Further analysis of the more recent cardiac rehabilitation program survey data documented that 16 of 20 cardiac arrest patients were categorized as high-risk coronary patients by standard risk stratification procedures; three of the four non-high-risk patients were participating in cardiac rehabilitation programs with intermittent ECG monitoring. Seventeen of 20 cardiac arrest patients were successfully resuscitated Van Camp and Peterson, 1989). Patients whose preexercise training risk status was considered high also had an increased rate of hospital readmission.

An observational study of myocardial infarction patients who were younger than 65 years of age reported no adverse effects in 37 high-risk patients during 2 years of medically supervised exercise training. No nonfatal reinfarction occurred in either high- or low-risk patients (Hedback and Perk, 1990).

An additional observational report of outpatient exercise rehabilitation that compared morning-hours exercise with afternoon-hours exercise reported an overall cardiac complication rate (syncope, arrhythmia, myocardial infarction, or sudden death) of 3/100,000 patient-hours for morning patients and 2.4/100,000 patient-hours for afternoon patients, a nonsignificant difference (Murray, Herrington, Pettus, et al., 1993).

Morbidity outcomes in addition to reinfarction rates were reported in seven randomized controlled trials. These included significantly less ST-segment depression at exercise testing in intervention patients compared with control patients DeBusk, Houston, Haskell, et al., 1979), no clinically significant adverse effects of 10 weeks of circuit weight training compared with aerobic training Kelemen, 1989), and no differences in measures of left ventricular performance after 6 months of exercise training compared with control status in male patients following myocardial infarction with baseline left ventricular ejection fractions of less than 40 percent (Giannuzzi, Tavazzi, Temporelli, et al., 1993). An additional randomized controlled trial reported no differences in ST-segment depression or ventricular arrhythmia during home exercise training compared with no-exercise controls (Hung, Gordon, Houston, et al., 1984). The final two randomized controlled reported no significant differences in "complications" in intervention patients compared with control patients DeBusk, Houston Miller, Superko, et al., 1994; Hambrecht, Niebauer, Marburger, et al., 1993).

### Conclusions

On the basis of the randomized controlled trials reported in the scientific literature, there is no evidence for reduction in cardiac morbidity, most specifically nonfatal reinfarction, as a result of exercise rehabilitation. No study documented an increase in morbidity comparing rehabilitation patients with control patients in 4,578 patients included in the controlled trials (randomized and nonrandomized) reviewed. No study reported reinfarction or other morbidity rates by gender or by age. Only one randomized controlled trial included patients with varied presentations of coronary disease (Haskell, 1978); all other randomized controlled trials were of patients following myocardial infarction.

The larger of the two surveys of adverse experiences during rehabilitative exercise training in 142 U.S. cardiac rehabilitation programs (1980-84) reported a very low rate of nonfatal reinfarction of 1/294,000 patient-hours ( Van Camp and Peterson, 1989). It should be emphasized that these 1980-84 survey data may not be applicable to contemporary treatment of coronary patients. Specifically, the widespread use of risk stratification procedures following myocardial infarction, the more aggressive management techniques including thrombolytic therapy and myocardial revascularization, as well as current pharmacologic therapies for postinfarction patients (e.g., beta blockers, ACE inhibitors) may further reduce reinfarction and morbidity in coronary patients. The current low nonfatal reinfarction rates may not be amenable to any further reduction by exercise training as a sole intervention. Morbidity outcome data must be obtained for older coronary patients, female patients, and higher risk patients participating in exercise rehabilitation. Appropriately designed and conducted exercise-based cardiac rehabilitation can safely be undertaken in appropriately selected patients undergoing individualized initial assessment and surveillance.

## Mortality and Safety Issues

RECOMMENDATION: On the basis of the meta-analytical data, total and cardiovascular mortality are reduced in patients following myocardial infarction who participate in cardiac rehabilitation exercise training, especially as a component of multifactorial rehabilitation.

### Scientific Evidence (Strength of Evidence = B)

The scientific evidence pertaining to the relationship of cardiac rehabilitation exercise training to mortality includes 31 scientific reports. Seventeen reports were from 16 randomized controlled trials (1 trial reported 3- and 10-year followup data), eight were nonrandomized controlled studies, and six were observational reports. In addition, two survey questionnaire reports provided information regarding mortality rates.

Four of the 16 randomized controlled trials reported a statistically significant decrease in mortality favoring rehabilitation versus control patients. Three-year coronary mortality and sudden death rates were significantly lower (p < .02) in patients following myocardial infarction with multifactorial cardiac rehabilitation starting 2 weeks after hospital discharge (Kallio, Hamalainen, Hakkila, et al., 1979). This beneficial outcome persisted at the 10-year followup (Hamalainen, Luurila, Kallio, et al., 1989). The largest center from a multicenter European trial of exercise-only rehabilitation in male patients following myocardial infarction reported significant reduction in total mortality favoring rehabilitation versus control patients (p < .01; Lamm, Denolin, Dorossiev, et al., 1982). In a randomized controlled trial that demonstrated mortality reduction associated with exercise training as the sole intervention, benefit was limited to patients with inferior wall myocardial infarction (p < .01) (Carson, Phillips, Lloyd, et al., 1982). The final randomized controlled trial that reported favorable reduction in total mortality compared myocardial infarction patients who received exercise rehabilitation with patients who received only counseling and usual care. Total mortality was significantly reduced (p = .03) in exercising patients compared with the combined counseling and usual-care patient groups (P.R.E. Cor Group, 1991). The 10 additional randomized controlled trials, which involved 4,747 patients, reported no difference in mortality between rehabilitation and control patients DeBusk, Houston Miller, Superko, et al., 1994; Hakkila, 1977; Hamalainen, Luurila, Kallio, et al., 1989; Haskell, Alderman, Fair, et al., 1994; Kentala, 1972; Marra, Paolillo, Spadaccini, et al., 1985; Shaw, 1981; Sivarajan, Bruce, Lindskog, et al., 1982; Vermeulen, Lie, and Durrer, 1983; Wilhelmsen, Sanne, Elmfeldt, et al., 1975). Two additional randomized controlled trials reported no mortality difference comparing high- and low-intensity exercise training groups (Rechnitzer, Cunningham, Andrew, et al., 1983; Worcester, Hare, Oliver, et al., 1993). These trials are summarized in Table 8. No randomized controlled trial reported excess mortality in rehabilitation groups compared with patient groups.

Table 8. Mortality in randomized controlled trials of exercise-based cardiac rehabilitation

Reference, Country | Patients | Intervention, Followup | | Outcome
Kentala (1972) Finland | Sample size: 152 (71 intervention, 81 control) Gender: 100% men Age: < 65 years Category: 6-8 weeks after MI | Intervention: Exercise intensity of heart rate 10 bpm below exercise test peak at baseline. 3 times/week for 20-minute sessions. Control group 1 session of consultation each month. Followup: 12 months | | Total mortality: 11 exercise, 11 control No significant difference between groups
Wilhelmsen, Sanne, Elmfeldt, et al. (1975) Sweden | Sample size: 315 (158 intervention, 157 control) Gender: 138 men intervention, 142 men control Age: 57 years or less Category: 3 months following MI | Intervention: Supervised exercise. 3 sessions/week for 0.5 hour/session at 80% baseline maximal exercise test heart rate. 9- month exercise duration. Followup: 4 years | | Total mortality: 28 exercise, 35 control (p = .40) No significant difference by type or place of death between groups
Hakkila (1977) Finland | Sample size: 350 (172 intervention, 178 control) Gender: 100% men Age: < 65 years Category: MI | Intervention: Supervised exercise 2 times/week Followup: 17-23 months | | CHD 1-year mortality: 6.5% exercise, 8.6% control CHD 2-year mortality: 10.4% exercise, 12.3% control No significant difference between groups
Kallio, Hamalainen, Hakkila, et al. (1979) Finland | Sample size: 325 (187 intervention, 138 control) Gender: 150 men intervention, 151 men control Age: < 65 years, mean 54 years Category: 2 weeks following hospital discharge after MI | Intervention: Multifactorial. Cycle ergometry supervised exercise "most intensive" first 3 months, details not specified. Health education and psychosocial advice. Followup: 3 years | | Coronary mortality: 18.6% intervention, 29.4% control (p = .02) Sudden death: 5.8% intervention, 14.4% control (p < .01) Mortality trends "similar" for men and women Total mortality: 21.8% intervention, 29.9% control (p < .10)
Shaw (1981) United States | Sample size: 651 (323 intervention, 328 control) Gender: 100% men Age: 30-64 years Category: Within 3 years following MI | Intervention: Supervised exercise 85% baseline maximal exercise test heart rate. First 8 weeks 24 minutes monitored aerobic exercise. 3 days/week; following 24 weeks supervised nonmonitored aerobic exercise 40 minutes 3 times/week. Followup: 3 years | | Total mortality: 4.6% exercise, 7.3% control CV mortality: 4.3% exercise, 6.1% control (p = .40)
Lamm, Denolin, Dorossiev, et al. (1982) Denmark | Sample size: 2,054 (randomization groups not specified) Gender: 100% men Age: Not specified Category: MI | Intervention: No details provided. Multicenter study (23 centers). Followup: 3 years | | 11/17 centers reported mortality favoring intervention vs. control (3 statistically significant, p < .05) Largest center (405 patients). Total mortality: 5.7% intervention, 15.6% control (p < .01).
Carson, Phillips, Lloyd, et al. (1982) United Kingdom | Sample size: 303 (151 intervention, 152 control) Gender: 100% men Age: < 70 years, 50-67 years Category: 6 weeks following MI. High-risk patients excluded. | Intervention: Supervised gymnasium exercise 2 times/week for 12 weeks. Details not specified. Followup: 2.1 years | | Total mortality: 8% exercise, 14% control (no significant difference) except inferior MI patients with 2% mortality exercise vs. 14% mortality control (p < .01)
Sivarajan, Bruce, Lindskog, et al. (1982) United States | Sample size: 258 (88 exercise, 86 exercise + teaching/counseling, 84 control) Gender: 80% men Age: 70 years and younger, mean 56-57 years Category: Uncomplicated MI | Setting: Home and rehabilitation center Intervention: Supervised weekly group exercise for 30 minutes. Intensity not specified. 3-month duration both groups + education/counseling, eight 1-hour group sessions weekly. Followup: 3 and 6 months | | Cardiac mortality at 6 months: 4% exercise-only, 5% exercise + education/counseling, 2% control No significant difference between groups
Vermeulen, Lie, and Durrer (1983) The Netherlands | Sample size: 98 (47 intervention, 51 control) Gender: 100% men Age: 40-55 years Category: 4-6 weeks following MI | Intervention: Multifactorial. Supervised exercise + social and psychological intervention. Followup: 5 years | | Cardiac death: 2 intervention, 5 control No significant difference between groups
Roman, Gutierrez, Luksic, et al. (1983) Chile | Sample size: 193 (93 intervention, 100 control) Gender: 86 men intervention, 87 men control Age: Mean 56 years intervention, 59 years control (no significant difference) Category: MI | Intervention: Supervised aerobic exercise 30 minutes 3 times/week for mean of 42 months at 70% maximal baseline exercise test heart rate Followup: Mean 42 months | | Total mortality: 3.6% exercise, 5.8% control No significant difference between groups Cardiac mortality: 2.9% exercise, 5.2% control (p < 0.1, < .01)
Rechnitzer, Cunningham, Andrew, et al. (1983) Canada | Sample size: 761 (390 high-intensity exercise, 371 low-intensity exercise) Gender: 100% men Age: 26-56 years, median 47 years Category: MI | Intervention: High-intensity (65-85% of estimated maximal oxygen uptake) or low-intensity (50% or less estimated maximal oxygen uptake). Supervised 2 times/week for mean of 3.3 years. Followup: Mean 3.3 years | | Fatal reinfarction: 15 high- intensity group, 13 low-intensity group No significant difference between groups
Marra, Paolillo, Spadaccini, et al. (1985) Italy | Sample size: 161 (81 intervention, 80 control) Gender: Not specified Age: 25-65 years Category: MI | Intervention: Supervised monitored aerobic exercise 1 hour 4 times/week at 80-90% maximal baseline exercise test heart rate for 8-9 weeks. Controls, home exercise cycling, walking, and calisthenics. Followup: 4.5 years | | Total mortality: 6 exercise, 5 control No significant difference between groups
Hamalainen, Luurila, Kallio, et al. (1989) Finland | Sample size: 375 (188 intervention, 187 control) Gender: 301 men, 74 women Age: < 65 years Category: Consecutive patients "a few weeks" following MI | Intervention: Multifactorial. Dietary, antismoking, and psychological counseling + exercise "tailored to individual capacity." Followup: 10 years | | Total mortality: 44% intervention, 52% control No significant difference between groups Sudden death: 24 (13%) intervention, 43 (23%) control (p = .01) Total coronary mortality: 35% intervention, 47% control (p = .02)
P.R.E. Cor Group (1991) France | Sample size: 182 (60 intervention, 61 usual care, 61 counseling) Gender: 100% men Age: < 65 years Category: Within 60 days of MI | Intervention: Exercise rehabilitation (RP) 6 weeks 3 times/week for 25 minutes at 80% maximal heart rate. 1 counseling (CP) session with medical team and 1 examination by cardiologist. Usual care (UC) with referral to family physician/cardiologist. Followup: Not specified | | Total mortality: RP = 0%, UC = 4/61 (7%), CP = 5/61 (8%) (p < .08) RP vs. CP + UC (p = .03)
Worcester, Hare, Oliver, et al. (1993) Australia | Sample size: 224 (108 high-intensity training, 116 low-intensity training) Gender: 100% men Age: Mean 54 years Category: MI | Intervention: Exercise training 30 minutes 70-85% maximal baseline heart rate 3 times/week for 8 weeks. Light exercise limited activity in classes 2 times/week for 8 weeks. Both groups encouraged to walk daily at home. Followup: 4 and 12 months | | Total mortality: 10 high-intensity exercise, 9 light exercise No significant difference between groups
DeBusk, Houston Miller, Superko, et al. (1994) United States | Sample size: 585 (293 intervention, 292 usual care) Gender: 79% men Age: < 70 years, mean 57 years Category: MI, 77% Caucasian. 62% college-educated or above. 42% smokers at entry. | Intervention: Nurse-directed case management for coronary risk reduction. Lipid-lowering medications for LDL cholesterol > 95 mg/dL at day 90. National Cholesterol Education Program Step II diet. Smoking cessation with relapse prevention with nicotine gum. Home exercise at 60-85% maximal baseline exercise test heart rate. Exercise 30 minutes 5 times/week with heart rate monitoring and self-monitoring logs. Intervention 6 months. Followup: 1 year | | Cardiac mortality: 3.8% intervention, 3.1% usual care Total mortality: 4.1% intervention, 3.4% usual care Neither difference statistically significant between groups
Haskell, Alderman, Fair, et al. (1994) United States | Sample size: 300 (72 of 145 medically treated, usual care; 74 of 139 PTCA usual care; 10 of 16 CABG usual care) Gender: 83% intervention and 92% usual care men Age: < 75 years, mean 57 years Category: Catheterization-documented CHD. Patients with left ventricular ejection fraction < 0.2 excluded. | Intervention: Multifactorial. Nurse- guided nutritional counseling, behavioral treatment for smoking, and lipid-lowering drugs prescribed on individual basis (90% intervention vs. 23% usual care). Home individual exercise prescription. Followup: 4 years | | Total cardiac events including fatal MI, nonfatal MI, subsequent PTCA or CABG surgery: 25 intervention, 44 usual care (p = .05) Cardiac or sudden unexplained death: 2 intervention, 3 usual care No significant difference between groups

Note: bpm = beats per minute; CABG = coronary artery bypass graft surgery; CHD = coronary heart disease; LDL = low-density lipoprotein; MI = myocardial infarction; PTCA = percutaneous transluminal coronary angioplasty.

Eight nonrandomized controlled trials reported outcomes. Two of these trials reported a statistically significant reduction in mortality in rehabilitation versus control patients ( Hedback, Perk, and Wodlin, 1993; Rechnitzer, Pickard, Paivio, et al., 1972). Three multifactorial nonrandomized controlled trials showed mortality difference between rehabilitation and control groups (Ben-Ari, Rothbaum, Linnemeir, et al., 1989; Hedback and Perk, 1987; Perk, Hedback, and Jutterdal, 1989). One study established significant mortality reduction only after 10 years of followup (Hedback, Perk, and Wodlin, 1993), compared with the 5-year followup data ( Hedback and Perk, 1987). No difference in mortality was noted in three other nonrandomized controlled trials in which exercise training was the sole intervention (Heath, Maloney, and Fure, 1987; Lee, Ice, Blessey, et al., 1979; Palatsi, 1976).

The six observational studies that reported mortality data had no control groups for comparison ( Crozier Ghilarducci, Holly, and Amsterdam, 1989; Fioretti, Baardman, Deckers, et al., 1988; Kellermann, Shemesh, Fisman, et al., 1990; Monpere, Francois, Brochier, et al., 1988; Shephard, Corey, and Kavanagh, 1981; van Dixhoorn, Duivenvoorden, Staal, et al., 1987). Two large survey reports establish low rates of cardiac death during rehabilitation exercise training: 1/116,400 patient-hours in the early years of rehabilitation (1960-77) ( Haskell, 1978) and 1/784,000 patient-hours in more recent years (1980-84) (Van Camp and Peterson, 1986). Caution regarding these rates of cardiac death is warranted the data represent an aggregate analysis of information received from cardiac rehabilitation programs that were sent survey questionnaires and provided data in a retrospective manner. Furthermore, the survey represents data from the 1980s and may not reflect contemporary management of coronary patients.

### Conclusions

A survival benefit among patients participating in exercise training as a component of multifactorial cardiac rehabilitation is suggested from review of the scientific data, but this benefit cannot be attributed solely to exercise training. The relatively low mortality rates reported in questionnaire surveys of supervised exercise rehabilitation and the inability of single studies to enroll adequate numbers of patients in a randomized controlled trial could underestimate the potential benefit of cardiac rehabilitation in reducing mortality rates. For this reason, the panel drew on meta-analyses to gain additional information about mortality outcomes. Two meta-analyses of 21 randomized controlled trials of cardiac rehabilitation established significant mortality reduction in rehabilitation patients compared with control patients (O'Connor, Buring, Yusuf, et al., 1989; Oldridge, Guyatt, Fischer, et al., 1988); the meta-analyses established an approximately 25-percent relative reduction in mortality at the 3-year followup in rehabilitation patients compared with control patients. This mortality reduction is similar to that with other interventions for patients with coronary disease (e.g., trials of beta-blocking drug therapy following myocardial infarction; ACE inhibitors therapy for left ventricular systolic dysfunction and heart failure). The meta-analyses of randomized controlled trials included more than 4,000 patients with coronary disease; the beneficial mortality outcome was greater in the 15 trials that used multifactorial cardiac rehabilitation compared with the seven trials that used exercise training as the sole intervention. Specifically, the odds ratio (proportion of events in intervention group divided by proportion of events in control group) for cardiovascular mortality comparing intervention with control patients at the 3-year followup was 0.74 in the multifactorial intervention compared with 0.85 in the exercise-only trials (O'Connor, Buring, Yusuf, et al., 1989).

Most studies involved principally male patients younger than 65 years old following myocardial infarction and excluded high-risk complex patients, thereby limiting the generalizability of the data. The percentage of females, when enrolled, was 20 percent or less. Furthermore, subsequent to the research studies cited as scientific evidence, the reduction in mortality was increased by nonrehabilitation interventions such as myocardial revascularization procedures and newer pharmacologic agents that have far more powerful effects on survival.

The randomized controlled trials that reported mortality rates included a total of 7,063 patients. In no trial was the rate of fatal events greater in the intervention group than in the control group.

Information obtained from two large surveys provided retrospective data from cardiac rehabilitation program responses to questionnaires (Haskell, 1978; Van Camp and Peterson, 1986). The proportion of fatal cardiac events occurring during or immediately following exercise training was low: 1/116,400 patient-hours of participation in supervised exercise training in the 1978 report Haskell, 1978) and 1/784,000 patient-hours in the 1986 report (Van Camp and Peterson, 1986). The data from both survey reports antedate the use of contemporary risk stratification procedures and contemporary medical and surgical therapies for coronary disease and heart failure. Further analysis of the more recent rehabilitation program survey data documented that 16 of 20 cardiac arrest patients were categorized as high risk by standard risk stratification methods and that three of the four non-high-risk patients were in programs with intermittent ECG monitoring. Only one patient was reported to exercise above the recommended exercise training level Van Camp and Peterson, 1989). However, in one randomized controlled trial patients who experienced cardiac arrest had been documented to exceed their prescribed training heart rate (Hambrecht, Niebauer, Marburger, et al., 1993).

No mortality data were reported by gender or patient age, nor was definitive information available regarding the effect of levels of supervision and ECG monitoring of exercise training.

## Pathophysiologic Measures

### Extent of Coronary Atherosclerosis

RECOMMENDATION: Cardiac rehabilitation exercise training as a sole intervention does not result in regression or limitation of progression of angiographically documented coronary atherosclerosis. When combined with intensive dietary intervention -- with and without lipid-lowering drugs -- exercise training may result in regression or limitation of progression of angiographically documented coronary atherosclerosis.

#### Scientific Evidence (Strength of Evidence for Lack of Efficacy of Exercise Training Only = A; Strength of Evidence for Efficacy of Multifactorial Intervention = B)

The scientific data that address the effect of exercise training on coronary atherosclerosis are based on five randomized controlled clinical trials (Hambrecht, Niebauer, Marburger, et al., 1993; Haskell, Alderman, Fair, et al., 1994; Nolewajka, Kostuk, and Rechnitzer, 1979; Ornish, Brown, Scherwitz, et al., 1990; Schuler, Hambrecht, Schlierf, et al., 1992b), one nonrandomized controlled study (Schuler, Hambrecht, Schlierf, et al., 1992a), and three observational studies Ferguson, Petitclerc, Choquette, et al., 1974; Kennedy, Spiekerman, Lindsey, et al., 1976; Lee, Ice, Blessey, et al., 1979).

All of these studies involved patients with cardiac catheterization-documented coronary disease. Ascertainment of regression or progression was based on serial coronary angiography. In the earlier studies, assessment was by visual inspection of the coronary angiogram. The more recent studies reported digitally processed coronary angiographic findings Hambrecht, Niebauer, Marburger, et al., 1993; Haskell, Alderman, Fair, et al., 1994; Ornish, Brown, Scherwitz, et al., 1990; Schuler, Hambrecht, Schlierf, et al., 1992a; Schuler, Hambrecht, Schlierf, et al.,1992b).

One of the five randomized controlled trials Nolewajka, Kostuk, and Rechnitzer, 1979), which used exercise training as the sole intervention, showed that atherosclerosis had a "tendency to progress," but there was no significant difference between the exercise and control populations. Two randomized controlled trials of multifactorial rehabilitation, including exercise training and intensive dietary intervention, showed significant improvement in coronary atherosclerosis (less progression and greater regression) in rehabilitation versus control populations Ornish, Brown, Scherwitz, et al., 1990; Schuler, Hambrecht, Schlierf, et al., 1992b). One study reported more favorable atherosclerotic changes in the exercise group than in the control group (p < .01) and correlated these changes with leisure time energy expenditure and change in LDL cholesterol levels (Hambrecht, Niebauer, Marburger, et al., 1993). Patients who expended less than 1,500 kilocalories per week showed no regression; regression was evident with an average energy expenditure of 2,200 kilocalories per week, but dietary changes were not addressed. The final randomized controlled trial of multifactorial rehabilitation and lipid-lowering drug therapy showed significant improvement in the rate of progression of coronary atherosclerotic lesions, when analyzed both by patient (p < .02) and by arterial segment (p < .002), in rehabilitation versus control populations Haskell, Alderman, Fair, et al., 1994).

The one nonrandomized controlled study of multifactorial rehabilitation showed improvement in atherosclerosis in the rehabilitation versus control population Schuler, Hambrecht, Schlierf, et al., 1992a). The three observational studies, all performed during the 1970s, involved only exercise training and showed no change in coronary atherosclerotic lesions (Ferguson, Petitclerc, Choquette, et al., 1974; Kennedy, Spiekerman, Lindsay, et al., 1976; Lee, Ice, Blessey, et al., 1979).

### Hemodynamic Measurements

RECOMMENDATION: Cardiac rehabilitation exercise training has no apparent effect on development of a coronary collateral circulation and produces no consistent changes in cardiac hemodynamic measurements at cardiac catheterization. Exercise training in patients with heart failure and a depressed ventricular ejection fraction produces favorable hemodynamic changes in the skeletal musculature. Cardiac rehabilitation exercise training is recommended to improve skeletal muscle functioning; it does not enhance cardiac hemodynamic function or promote development of a coronary collateral circulation.

#### Scientific Evidence (Strength of Evidence = B)

The effect of exercise training on hemodynamic variables was examined in five observational studies ( Ignone, Giordano, and Tavazzi, 1988; Kennedy, Spiekerman, Lindsay, et al., 1976; Lee, Ice, Blessey, et al., 1979; Letac, Cribier, and Desplanches, 1977; Sullivan, Higginbotham, and Cobb, 1988). Four involved patients with myocardial infarction or angina pectoris, one included only patients with a decreased ejection fraction (Lee, Ice, Blessey, et al., 1979), and another involved myocardial infarction patients with residual myocardial ischemia Ignone, Giordano, and Tavazzi, 1988). The fifth observational study was limited to patients with heart failure and a decreased ejection fraction (Sullivan, Higginbotham, and Cobb, 1988). The hemodynamic measurements were measured at cardiac catheterization in four studies Kennedy, Spiekerman, Lindsay, et al., 1976; Lee, Ice, Blessey, et al., 1979; Letac, Cribier, and Desplanches, 1977; Sullivan, Higginbotham, and Cobb, 1988) and by Swan-Ganz catheterization, with and without exercise, in one study (Ignone, Giordano, and Tavazzi, 1988). All studies involved small numbers of middle-age men, thereby limiting the generalizability of the results.

Three studies of coronary patients ( Kennedy, Spiekerman, Lindsay, et al., 1976; Lee, Ice, Blessey, et al., 1979; Letac, Cribier, and Desplanches, 1977), including one in patients with a decreased ejection fraction (Lee, Ice, Blessey, et al., 1979), showed no significant changes in a variety of hemodynamic measurements, at rest or with exercise, as a result of exercise training. In postinfarction patients with residual myocardial ischemia, there were no significant changes in pulmonary capillary wedge pressure (PCWP) at rest or with maximal exercise after 4 weeks of exercise training (Ignone, Giordano, and Tavazzi, 1988), but a decrease in PCWP pressure was observed at a submaximal workload (p < .05). Arteriovenous oxygen (AVO[sub2]) difference did not change at rest or with submaximal exercise, but increased significantly at a maximal workload after exercise training (p < .05). Cardiac index did not change significantly at rest or at submaximal exercise, but increased significantly (p < .01) at peak exercise. There were no significant changes in stroke volume or systemic vascular resistance. The observational study of 12 patients with heart failure and a decreased ejection fraction showed no significant change in rest or exercise cardiac output after 4-6 months of exercise training (Sullivan, Higginbotham, and Cobb, 1988). Systemic AVO[sub2] difference increased significantly (p < .05), but no changes occurred in right atrial, pulmonary capillary wedge, and pulmonary artery pressures. Peripheral hemodynamic measurements showed no significant changes in rest or submaximal exercise leg blood flow, oxygen delivery, vascular resistance, or AVO[sub2] difference. At peak exercise, however, leg maximal oxygen consumption increased (p < .05), leg vascular resistance decreased (p < .06), and leg VO[sub2]max increased (p < .01); the increase in maximal cardiac output correlated with an increase in maximal oxygen uptake; furthermore, the number of hours of exercise per week correlated with the increase in peak oxygen consumption after exercise training.

### Myocardial Perfusion and/or Evidence of Myocardial Ischemia

RECOMMENDATION: Cardiac rehabilitation exercise training decreases myocardial ischemia as measured by exercise ECG testing, ambulatory ECG recording, and radionuclide perfusion imaging. Cardiac rehabilitation exercise training is recommended to improve these measures of myocardial ischemia.

#### Scientific Evidence (Strength of Evidence = B)

The effect of exercise training on myocardial perfusion and/or evidence of myocardial ischemia was addressed by six randomized controlled trials (DeBusk, Houston, Haskell, et al., 1979; Froelicher, Jensen, Genter, et al., 1984; Hung, Gordon, Houston, et al., 1984; Naughton, Bruhn, and Lategola, 1968; Sebrechts, Klein, Ahnve, et al., 1986; Todd and Ballatyne, 1992), two nonrandomized controlled studies ( Ades, Waldmann, and Gillespie, 1995; Schuler, Hambrecht, Schlierf, et al., 1992a), and three observational studies (Ferguson, Petitclerc, Choquette, et al., 1974; Kennedy, Spiekerman, Lindsay, et al., 1976; Lee, Ice, Blessey, et al., 1979). All of these studies included predominantly or exclusively male patients, generally of middle age (mean age in the 50s), thereby limiting the generalizability of the data. One study involved elderly coronary patients (Ades, Waldmann, and Gillespie, 1995).

One randomized controlled trial showed significant improvement in ischemic ST-segment changes during sequential exercise testing, favoring exercise versus control patients (p < .05, DeBusk, Houston, Haskell, et al., 1979). A nonrandomized controlled study in elderly patients showed no change in exercise test ST-segment depression between exercise and control patients (Ades, Waldmann, and Gillespie, 1995). Ambulatory ECG measures of ischemic ST-segment abnormality were significantly reduced in exercising patients compared with control patients (Todd and Ballatyne, 1992).

Myocardial perfusion scanning in a randomized controlled trial showed a significant reduction in reversible perfusion defects in exercise patients compared with control patients, but only in patients without ECG ST-segment depression at exercise training (Hung, Gordon, Houston, et al., 1984). In a randomized controlled trial, thallium perfusion defects in patients with angina decreased in exercise patients and increased in control patients, with a statistically significant difference between groups (Froelicher, Jensen, Genter, et al., 1984). Computer-analyzed myocardial perfusion scanning showed a statistically significant greater improvement at 1 year in exercising patients compared with control stable coronary patients, 77 percent of whom had prior myocardial infarction Sebrechts, Klein, Ahnve, et al., 1986). A nonrandomized controlled study also reported a statistically significant reduction in thallium perfusion defects in exercise patients compared with control patients Schuler, Hambrecht, Schlierf, et al., 1992a).

### Myocardial Contractility, Ventricular Wall Motion Abnormalities, and/or Ventricular Ejection Fraction

RECOMMENDATION: Cardiac rehabilitation exercise training has little effect on ventricular ejection fraction and regional wall motion abnormalities. The effect of exercise training on left ventricular function in patients after anterior wall Q-wave myocardial infarction with left ventricular dysfunction is inconsistent. Cardiac rehabilitation exercise training is not recommended to improve measures of ventricular systolic function.

#### Scientific Evidence (Strength of Evidence = B)

The effect of exercise training on myocardial contractility, ventricular wall motion abnormalities, and/or ventricular ejection fraction was studied in eight randomized controlled trials, five nonrandomized controlled studies, and eight observational studies. Myocardial function was studied at cardiac catheterization, by two-dimensional echocardiography or by exercise radionuclide ventriculography. The patients were predominantly or exclusively men, usually of middle age, and rarely older than age 65, thereby limiting the generalizability of the data. One study involved elderly coronary patients (Ades, Waldmann, and Gillespie, 1995).

Two of the eight randomized controlled trials that evaluated left ventricular ejection fraction showed significant improvement in exercise patients compared with control patients Fletcher, Dunbar, Felner, et al., 1994; Ornish, Scherwitz, Doody, et al., 1983). The remaining six studies reported no statistically significant differences between groups ( Froelicher, Jensen, Genter, et al., 1984; Giannuzzi, Tavazzi, Temporelli, et al., 1993; Giannuzzi, Temporelli, Tavazzi, et al., 1992; Grodzinski, Jette, Blumchen, et al., 1987; Hung, Gordon, Houston, et al., 1984; Nolewajka, Kostuk, and Rechnitzer, 1979).

Five nonrandomized controlled studies reported outcomes pertaining to left ventricular function. No beneficial effects were documented in three (Ades, Waldmann, and Gillespie, 1995; Hands, Briffa, Henderson, et al., 1987; Hertzeanu, Shemesh, Aron, et al., 1993), and one reported deterioration in left ventricular function following anterior Q-wave myocardial infarction in exercise patients compared with nonrandomized control patients (Jugdutt, Michorowski, and Kappagoda, 1988). Subsequent randomized controlled trials documented comparable spontaneous deterioration in ventricular function in patients with a decreased ejection fraction following myocardial infarction, both with and without exercise rehabilitation Giannuzzi, Tavazzi, Temporelli, et al., 1993; Giannuzzi, Temporelli, Tavazzi, et al., 1992). One study of patients following successful PTCA without myocardial infarction showed an increase in ejection fraction in the exercise group compared with the control group (Ben-Ari, Rothbaum, Linnemeir, et al., 1989).

The eight observational studies reported inconsistent changes in ventricular function (Arvan, 1988; Ehrman, Keteyian, Fedel, et al., 1992; Kavanagh, Yacoub, Mertens, et al., 1989; Kellermann, Shemesh, Fisman, et al., 1990; Keteyian, Ehrman, Fedel, et al., 1990; Lee, Ice, Blessey, et al., 1979; Niset, Coustry-Degre, and Degre, 1988; Sullivan, Higginbotham, and Cobb, 1988). In one study, the increase in rate-pressure product with exercise training was comparable in patients with and without an increase in ejection fraction (Kellermann, Shemesh, Fisman, et al., 1990). One observational study showed an improved fraction only in patients without baseline ST-segment abnormalities at exercise testing and another study only in patients with ST-segment elevation at baseline exercise testing, with no difference between patients with anterior and inferior infarction Arvan, 1988). Circuit weight training and aerobic training differed little in their effects on myocardial function. No significant change in ejection fraction occurred with exercise training in two studies of patients with left ventricular dysfunction and a diminished ejection fraction, but no worsening of ejection fraction was described (Arvan, 1988; Kellermann, Shemesh, Fisman, et al., 1990).

### Occurrence of Cardiac Arrhythmias

RECOMMENDATION: Rehabilitative exercise training has inconsistent effects on ventricular arrhythmias.

#### Scientific Evidence (Strength of Evidence = B)

Four randomized controlled trials and one observational study reported effects pertaining to cardiac arrhythmias. Two randomized controlled trials showed favorable reduction in ventricular arrhythmias comparing exercise patients with control patients DeBusk, Houston, Haskell, et al., 1979; Hamalainen, Luurila, Kallio, et al., 1989). One randomized controlled trial documented no significant difference in ventricular arrhythmia frequency or severity with 24-hour ambulatory ECG comparing exercise patients and control patients (Todd and Ballatyne, 1992). A randomized controlled trial reported more malignant ventricular arrhythmia on 24-hour ambulatory ECG during exercise-training days in exercise patients compared with control patients ( Hoberg, Schuler, Kunze, et al., 1990). The one observational study showed no difference in premature ventricular contractions at exercise testing at baseline versus following exercise training (Ignone, Giordano, and Tavazzi, 1988).

### Conclusions

A number of scientific reports have described pathophysiologic outcomes of exercise training -- changes in the extent of coronary atherosclerosis; in hemodynamic measurements; in myocardial perfusion or evidence of myocardial ischemia; in myocardial contractility, ventricular wall motion abnormalities, or ventricular ejection fraction; and in the occurrence of cardiac arrhythmias. These studies explored and at times interrelated pathophysiologic mechanisms whereby exercise training may engender benefits or harms. However, all reports that described the pathophysiologic outcomes of exercise training involved predominantly or exclusively male patients, typically of middle age, with few or no elderly patients studied; these demographic constraints limit the generalizability of the outcome data.

Multifactorial cardiac rehabilitation, including exercise training and dietary intervention, with and without the use of lipid-altering drugs, effected regression or limited progression of angiographically documented coronary atherosclerosis. The effect of exercise training as a sole intervention is not impressive. It should be noted that subsequent coronary events may be related to factors other than change in arterial luminal diameter, that is, factors promoting plaque stability versus rupture, which may be related to circulating lipid levels, among others.

Development of an angiographically documented coronary collateral circulation has not been demonstrated with exercise training; it occurred only with progression of the underlying coronary atherosclerosis. No prominent or consistent changes in cardiac hemodynamic measurements at cardiac catheterization occurred as a result of exercise training. In patients with heart failure and a decreased ventricular ejection fraction, improvement occurred in leg hemodynamic parameters with exercise, supporting the favorable effect of exercise training on the skeletal musculature.

The beneficial effects of exercise training on myocardial perfusion and/or measures of myocardial ischemia included less ischemic ECG abnormalities at exercise testing and during ambulatory ECG recording. Resolution of reversible thallium perfusion defects in the randomized controlled trials was also greater in exercising patients than in nonexercising patients.

Most of the studies that examined the effect of usual rehabilitative exercise training on measures of myocardial function showed no significant difference in ejection fraction or regional wall motion abnormalities between exercising and control groups. Apparently spontaneous improvement in resting ejection fraction after myocardial infarction occurred in both exercise and control populations in several randomized clinical trials, rendering suspect described improvements in ejection fraction in observational studies. A nonrandomized controlled study of patients following anterior Q-wave myocardial infarction and decreased ejection fraction showed worsening of ejection fraction and wall motion asynergy in exercising patients compared with nonexercising patients (Jugdutt, Michorowski, and Kappagoda, 1988). Two subsequent randomized controlled trials in patients following anterior Q-wave myocardial infarction with baseline decreased ejection fraction documented comparable spontaneous deterioration in global and regional left ventricular function in exercise and control patients Giannuzzi, Tavazzi, Temporelli, et al., 1993; Giannuzzi, Temporelli, Tavazzi, et al., 1992).

Studies that described changes in ventricular arrhythmia related to exercise rehabilitation provide inconsistent outcomes. No randomized controlled trial reported a significant arrhythmia-related adverse clinical outcome.

## Patients With Heart Failure and Cardiac Transplantation

### Heart Failure

RECOMMENDATION: Rehabilitative exercise training in patients with heart failure and moderate-to-severe left ventricular systolic dysfunction improves functional capacity and improves symptoms. These changes usually occur without changes in left ventricular function. Cardiac rehabilitation exercise training in patients with heart failure and left ventricular systolic dysfunction is recommended to attain functional and symptomatic improvement but with a potentially higher likelihood of adverse events.

#### Scientific Evidence (Strength of Evidence = A)

Data regarding the role of exercise training in patients with heart failure derive from five randomized controlled trials, three nonrandomized controlled studies, and four observational reports.

One randomized controlled trial reported statistically significant improvement in measures of functional capacity, resting ejection fraction, and exercise ejection fraction in exercise patients compared with control patients Grodzinski, Jette, Blumchen, et al., 1987).

A randomized crossover design study showed significant decreases in heart rate and rate-pressure product, as well as a decrease in symptoms, after 8 weeks of exercise training compared with 8 weeks of rest. Peak oxygen consumption and exercise duration also increased significantly following exercise training Coats, Adamopoulos, Meyer, et al., 1990). A study that compared placebo with ACE inhibitor treatment -- with and without exercise training -- showed the greatest improvement in symptomatic status and lowest rate-pressure product in heart failure patients with a combination of ACE inhibitor treatment and exercise training. Significant increase in peak oxygen consumption and exercise duration occurred following exercise training with and without ACE inhibitor treatment (Meyer, Casadei, Coats, et al., 1991). In this study of 15 patients, one died suddenly during the ACE inhibitor treatment, and another patient developed progressive heart failure during the placebo-training phase requiring withdrawal from the study.

Two reports of a randomized controlled multicenter trial showed significant improvement in exercise capacity and exercise duration, as well as delay in the onset of anaerobic threshold, favoring cardiac rehabilitation exercise patients with ventricular asynergy after Q-wave anterior myocardial infarction. No significant difference in left ventricular dysfunction in myocardial infarction patients with baseline low ejection fraction was noted between exercise and control patients (Giannuzzi, Tavazzi, Temporelli, et al., 1993; Giannuzzi, Temporelli, Tavazzi, et al., 1992). There was no difference in improvement in exercise capacity with ejection fractions above and below 40 percent.

One nonrandomized controlled study of patients with anterior myocardial infarction and diminished ejection fraction showed a significantly greater increase in asynergy and decrease in ejection fraction in exercise patients compared with control patients Jugdutt, Michorowski, and Kappagoda, 1988). Another nonrandomized controlled trial compared high-and low-risk patients following myocardial infarction and reported no exercise-related complications and a comparable increase in exercise tolerance in high- and low-risk patients Hedback and Perk, 1990). A third nonrandomized controlled trial of patients following myocardial infarction with low ejection fractions showed significantly greater arrhythmia at ambulatory electrocardiography in control patients compared with exercise patients (Hertzeanu, Shemesh, Aron, et al., 1993).

Four observational studies also involved patients with diminished left ventricular ejection fraction Arvan, 1988; Kellermann, Shemesh, Fisman, et al., 1990; Lee, Ice, Blessey, et al., 1979; Sullivan, Higginbotham, and Cobb, 1988). In one of these studies, adverse cardiovascular outcomes were noted in 3 of the 16 patients during exercise training (1 sudden death, 1 progressive heart failure, and 1 prolonged fatigue that resulted in dropout from the study); absence of a control group limits assessment Sullivan, Higginbotham, and Cobb, 1988).

#### Conclusions

In the early years of exercise rehabilitation, cardiac enlargement, decreased left ventricular ejection fraction, and overt cardiac failure were considered relative or absolute contraindications to exercise training. Only in recent years has exercise training been undertaken in these patients; therefore, the studies that are available are recent and relatively few in number. Even these recent trials reflect only limited concomitant use of contemporary vasodilator drug therapies, particularly ACE inhibitors, which are now considered the standard of care for heart failure.

The large randomized placebo-controlled clinical trials of inhibitor medications in patients with decreased left ventricular systolic function reported reductions in morbidity and mortality in patients with coronary disease (p = .004, SOLVD Investigators, 1991; SOLVD Investigators, 1992) and following myocardial infarction (p = .014; Pfeffer, Braunwald, Moye, et al., 1992). The panel concurs with the recommendation of the AHCPR clinical practice guideline Heart Failure: Evaluation and Care of Patients With Left-Ventricular Systolic Dysfunction that "patients with heart failure due to left-ventricular systolic dysfunction should be given a trial of ACE inhibitors unless specific contraindications exist" (Konstam, Dracup, Baker, et al., 1994).

Most studies of exercise training of patients with heart failure and moderate-to-severe left ventricular dysfunction do not demonstrate deterioration in left ventricular function. Peripheral (skeletal muscle) adaptations appear to mediate the improvement in exercise tolerance. A combination of left ventricular dysfunction and residual myocardial ischemia may limit trainability. Exercise training augments the symptomatic and functional benefits of ACE inhibitor therapy. Low- to moderate-intensity exercise and home exercise regimens provide benefit, but adverse events can occur in this high-risk patient group.

In summary, although limited by small numbers and young populations consisting predominantly of men, and with coronary disease as the major etiology of heart failure, exercise training in patients with heart failure and diminished ventricular systolic dysfunction resulted in documented improvement in functional capacity. Only one study showed deterioration in ventricular function. Importantly, there was no correlation of improvement in functional capacity with improvement in ejection fraction. Data from one study reinforced the hypothesis that the favorable training effect in these patients was due predominantly to adaptations in the peripheral circulation and skeletal musculature rather than adaptations in the cardiac musculature. Several studies were short-term; seven involved exclusively or partly home exercise. Adverse effects in one observational study warrant concern despite no excess of adverse events in randomized controlled trials (Jugdutt, Michorowski, and Kappagoda, 1988).

### Cardiac Transplantation

RECOMMENDATION: Rehabilitative exercise training in patients following cardiac transplantation improves measures of exercise tolerance and is recommended for this purpose. Lack of control populations limits the ascertainment of spontaneous improvement.

#### Scientific Evidence (Strength of Evidence = B)

No randomized controlled trials addressed the effect of training on patients after cardiac transplantation. The scientific database includes one nonrandomized controlled trial and four observational studies.

The nonrandomized controlled trial compared 36 male transplant patients with age-matched normal controls. Following exercise training, patients following transplantation had a higher resting heart rate, decreased peak exercise heart rate, increased resting blood pressure, and decreased peak systolic blood pressure compared with normal controls. No change occurred in peak systolic blood pressure or rate-pressure product. A statistically significant increase in peak oxygen consumption was observed in highly adherent versus poorly adherent exercising transplantation patients Kavanagh, Yacoub, Mertens, et al., 1988).

The four observational studies reported an increase in functional capacity following exercise training Ehrman, Keteyian, Fedel, et al., 1992; Kavanagh, Yacoub, Mertens, et al., 1989; Keteyian, Ehrman, Fedel, et al., 1990; Niset, Coustry-Degre, and Degre, 1988).

A study of 105 ambulatory cardiac transplant candidates involved maximal medical therapy and nonsupervised prescribed walking. Patients were instructed to walk continuously to a target level of 20-30 minutes or 2 miles four times per week, were taught to check heart rate response, and were instructed to exercise at a level close to baseline exercise test-determined anaerobic threshold. Thirty-eight of 68 clinically stable patients showed significant improvement in peak maximal oxygen consumption and peak exercise tolerance, and an increase in anaerobic threshold and a reduction in resting heart rate (p < .05 for all parameters). After an average of 6 months of treatment, 31 of these 38 patients had improved sufficiently to be removed from the transplant list. The actuarial survival of these 31 patients was 97 percent at 1 year and 92 percent at 2 years (Stevenson, Steimle, Fonarow, et al., 1995).

#### Conclusions

Cardiac transplantation is a relatively recent surgical intervention; even more recent for cardiac transplantation patients is the frequent application of exercise training Wenger, Haskell, Kanter, et al., 1991). The few studies cited above provide valuable information for the management of these medically complex patients, who are often markedly deconditioned prior to cardiac transplantation. Pretransplantation rehabilitative strength training may enhance preoperative status and operative recovery. Effects of strength training in cardiac transplantation patients require further study.

## Elderly Patients

RECOMMENDATION: Elderly coronary patients have exercise trainability comparable to that of younger patients participating in similar exercise rehabilitation. Elderly female and male patients show comparable improvement. Referral to and participation in exercise rehabilitation is less frequent at elderly age, especially for elderly females. No complications or adverse outcomes of exercise training at elderly age were described in any study. Elderly patients of both genders should be strongly encouraged to participate in exercise-based cardiac rehabilitation.

### Scientific Evidence (Strength of Evidence = B)

The data on exercise rehabilitation at elderly age are derived from one nonrandomized controlled study and six observational studies, four of which compared older with younger coronary patients. Patients up to age 82 were included, and the elderly patients included a significant proportion of women.

Rates of entry into cardiac rehabilitation were substantially lower among elderly patients than among younger patients Ades, Hanson, Gunther, et al., 1987; Lavie, Milani, and Littman, 1993), and older women were even less likely to be referred for exercise rehabilitation than were older men (Ades, Waldmann, Polk, et al., 1992).

The nonrandomized controlled trial also documented statistically significant improvement in measures of exercise tolerance after exercise rehabilitation, with no significant difference between older and younger patients (Ades, Waldmann, and Gillespie, 1995). Patients older and younger than 70 years of age had comparable responses to exercise training, and women and men showed comparable improvement (Ades, Waldmann, and Gillespie, 1995).

The six observational studies documented statistically significant improvement in exercise tolerance in both older and younger patients (Ades and 1990; Ades, Hanson, Gunther, et al., 1987; Ades, Waldmann, Poehlman, et al., 1993; Ades, Waldmann, Polk, et al., 1992; Lavie, Milani, and Littman, 1993; Williams, Maresh, Esterbrooks, et al., 1985) as well as comparable improvement in older men versus older women (Ades, Waldmann, Polk, et al., 1992) and in patients age 62-70 years versus patients older than 70 years (Ades, Waldmann, Poehlman, et al., 1993). Elderly patients were less fit after a coronary event, in part because of lesser fitness prior to the event; a lower peak exercise capacity was characteristic of elderly patients, both at study entry and at completion of exercise training. There was a comparable increase in maximal oxygen uptake in elderly women and elderly men -- 17 percent and 19 percent, respectively (Ades, Waldmann, Polk, et al., 1992). Adherence to exercise training was high (90 percent) (Williams, Maresh, Esterbrooks, et al., 1985), and significant reduction in coronary risk factors occurred in elderly patients who participated in multifactorial cardiac rehabilitation (Lavie, Milani, and Littman, 1993).

### Conclusions

Elderly patients constitute a high percentage of patients with myocardial infarction, CABG, and PTCA. Elderly patients are also at high risk of disability following a coronary event. Recent trials of exercise rehabilitation have begun to include patients over 65 years of age and to specifically evaluate outcomes in the elderly coronary patient population.

Although few studies and no randomized controlled trials addressed the efficacy and safety of exercise training and multifactorial rehabilitation at elderly age, the available studies provide important new information for current clinical practice.

Special effort is recommended to overcome the obstacles to entry and participation in cardiac rehabilitation services for elderly patients.