# Overview

## Incidence and Prevalence

The central purpose of this Clinical Practice Guideline is to define the scientific basis for recommendations for provision of cardiac rehabilitation services.

Recommendations in this Clinical Practice Guideline are intended for health professionals caring for patients who might be candidates for cardiac rehabilitation services as well as clinicians involved in the provision of cardiac rehabilitation services. In addition, the guideline is intended to provide information to patients, their families, and others with interest in cardiac rehabilitation.

## Definitions and Goals

The panel reviewed a number of definitions of cardiac rehabilitation presented by authoritative groups: the World Health Organization (WHO) in 1964 (World Health Organization Expert Committee, 1964), the ACC in 1986 (Parmley, 1986) supplemented by Task Force Reports in 1990 and 1991 ( Wenger, Balady, Cohen, et al., 1990; Wenger, Haskell, Kanter, et al., 1991), the ACP in 1988 ( American College of Physicians, 1988), and an updated WHO report in 1993 (World Health Organization Expert Committee, 1993). The definition of cardiac rehabilitation used by the panel is based on a 1988 assessment by the U.S. Public Health Service of cardiac rehabilitation, which stated the following:

cardiac rehabilitation services are comprehensive, long-term programs involving medical evaluation, prescribed exercise, cardiac risk factor modification, education, and counseling. These programs are designed to limit the physiologic and psychological effects of cardiac illness, reduce the risk for sudden death or reinfarction, control cardiac symptoms, stabilize or reverse the atherosclerotic process, and enhance the psychosocial and vocational status of selected patients. Cardiac rehabilitation services are prescribed for patients who (1) have had a myocardial infarction; (2) have had coronary bypass surgery; or (3) have chronic stable angina pectoris. The services are in three phases beginning during hospitalization, followed by a supervised ambulatory outpatient program lasting 3-6 months, and continuing in a lifetime maintenance stage in which physical fitness and risk factor reduction are accomplished in a minimally supervised or unsupervised setting (Feigenbaum and Carter, 1988).

This definition does not fully recognize the pivotal role of the patient. The panel also advocates active assistance to enable the patient's acquisition of the knowledge, skills, and behaviors that will optimize adherence.

The U.S. Public Health Service assessment further noted that cardiac rehabilitation exercise training could be provided with little risk of complications or adverse events (Feigenbaum and Carter, 1988). A more recent Public Health Service document extended prior cardiac rehabilitation recommendations, stating that "the Health Care Financing Administration (HCFA) previously determined that cardiac rehabilitation programs are reasonable and necessary for patients who have had a myocardial infarction or coronary artery bypass surgery (CABG) or have stable angina pectoris," and that "heart transplant patients and patients who have undergone percutaneous transluminal coronary angioplasty or heart valve surgery could benefit from prescribed cardiac rehabilitation programs" (Agency for Health Care Policy and Research, 1991).

## Background

During the past three decades, changes in the delivery of rehabilitative care for patients with CHD have reflected changes in the demography and characteristics of the coronary population, as well as changes in treatment strategies for coronary patients. In the early years of cardiac rehabilitation, most patients enrolled in exercise training programs were those who had recovered from uncomplicated myocardial infarction (Bengtsson, 1983; Carson, Phillips, Lloyd, et al., 1982; DeBusk, Houston, Haskell, et al., 1979; Hung, Gordon, Houston, et al., 1984; Hung, McKillip, Savin, et al., 1982; Kallio, Hamalainen, Hakkila, et al., 1979; Rechneitzer, Cunningham, Andrew, et al., 1983; Vermeulen, Lie, and Durrer, 1983; Wilhelmsen, Sanne, Elmfeldt, et al., 1975). In subsequent years, patients with complications of myocardial infarction were considered for more limited and gradual exercise rehabilitation (Giannuzzi, Tavazzi, Temporelli, et al., 1993; Jugdutt, Michorowski, and Kappagoda, 1988). Many patients who currently receive rehabilitative services are recovering from CABG, PTCA, and other forms of myocardial revascularization (Ben-Ari, Rothbaum, Linnemeir, et al., 1989; Heath, Maloney, and Fure, 1987; Schuler, Hambrecht, Schlierf, et al., 1992b). With aging of the U.S. population, coronary rehabilitative care is now provided to a sizable number of elderly patients, many of whom have severe and complicated coronary illness (Ades and Grunvald, 1990; Ades, Hanson, Gunther, et al., 1987; Ades, Huang, and Weaver, 1992; Ades, Waldmann, and Gillespie, 1995; Crosby, Paternostro-Bayles, Cottington, et al., 1989; Hedback, Perk, Engvall, et al., 1990; Hoffmann, Duba, Lengyel, et al., 1987; Hung, McKillip, Savin, et al., 1982; Lavie, Milani, and Littman, 1993; Williams, Maresh, Esterbrooks, et al., 1985): residual myocardial ischemia, compensated heart failure, controlled but serious arrhythmias, and implanted cardiac pacemakers. Many categories of patients once arbitrarily excluded from exercise rehabilitation currently derive benefit from more gradual and more protracted and often supervised exercise training, combined with education, counseling, and behavioral strategies to assist them to achieve coronary risk reduction and other cardiovascular health-related goals; psychosocial assessments and interventions; and occupational assessment and vocational counseling ( Ades, Hanson, Gunther, et al., 1987; Ben-Ari, Rothbaum, Linnemeir, et al., 1989; Giannuzzi, Tavazzi, Temporelli, et al., 1993; Heath, Maloney, and Fure, 1987; Hoffmann, Duba, Lengyel, et al., 1987; Hung, McKillip, Savin, et al., 1982; Jugdutt, Michorowski, and Kappagoda, 1988; Lavie, Milani, and Littman, 1993; Schuler, Hambrecht, Schlierf, et al., 1992b).

AHCPR, the National Heart, Lung, and Blood Institute (NHLBI), and the AACVPR recognize that the awareness and understanding of the roles of cardiac rehabilitation services vary considerably among physicians, other health care providers, third-party payers, and cardiac patients and their families. Although patients with CHD, particularly following an acute coronary event, have been classically regarded as appropriate candidates, only 11 percent of such patients were estimated to have participated in formal cardiac rehabilitation programs (Leon, Certo, Comoss, et al., 1990). In recent years, participation in cardiac rehabilitation programs has become more common. For example, 38 percent of the U.S. patients and 32 percent of Canadian patients with acute myocardial infarction who were enrolled in the Global Utilization of Streptokinase and t-PA for Occluded Coronary Arteries (GUSTO) Trial were involved in cardiac rehabilitation programs (Mark, Naylor, Hlatky, et al., 1994).

Rehabilitative care of the cardiac patient addresses the limitations caused by adverse physiologic and emotional consequences of coronary and other cardiac disease. Identification of patients at risk for proximate coronary events (i.e., risk stratification) is the basis for determining appropriate medical and surgical therapeutic strategies ( American Association of Cardiovascular and Pulmonary Rehabilitation, 1991; American Association of Cardiovascular and Pulmonary Rehabilitation, 1995; Parmley, 1986) before rehabilitative care can be instituted. Risk stratification is based on physiologic assessment of patients with CHD and determines the presence and extent of myocardial ischemia, ventricular systolic dysfunction, and ventricular arrhythmias. Specific approaches to risk stratification are presented in Chapter 4. Patients at low or moderate risk for proximate coronary events typically undergo early rehabilitative care, particularly early accelerated exercise rehabilitation ( DeBusk, Houston Miller, Superko, et al., 1994; Hambrecht, Niebauer, Marburger, et al., 1993). The major goals of rehabilitative care are to lessen the risk of future coronary events (Haskell, Alderman, Fair, et al. 1994; Hedback, Perk, and Wodlin, 1993; van Dixhoorn, Duivenvoorden, Staal, et al., 1987), control symptoms arising from the coronary disease (Ornish, Brown, Scherwitz, et al., 1990), improve overall functional status, and optimize and maintain myocardial and musculoskeletal performance (Coats, Adamopoulos, Meyer, et al., 1990; Meyer, Casadei, Coats, et al., 1991). Interventions designed to retard the progression or induce regression of the underlying atherosclerotic process are paramount (Hambrecht, Niebauer, Marburger, et al., 1993; Haskell, Alderman, Fair, et al. 1994; Schuler, Hambrecht, Schlierf, et al., 1992b). Psychosocial risk factors have only recently been well recognized and now receive requisite attention in the assessment phase of cardiac rehabilitation.

The rehabilitative care strategies combine goals of assessing, enhancing, and maintaining physiologic, psychosocial, and vocational status appropriate to the individual patient's needs and desires. This combination of strategies is termed "multifactorial intervention," a term used throughout this guideline; others have used the term "multidisciplinary intervention." The components of rehabilitative care addressed in this guideline can be provided by physicians, nurses, exercise physiologists, behavioral specialists, dietitians, physical therapists, or occupational therapists with appropriate training and experience (American Association of Cardiovascular and Pulmonary Rehabilitation, 1995; American Heart Association, 1994; DeBusk, Houston Miller, Superko, et al., 1994; Haskell, Alderman, Fair, et al. 1994). Depending on the setting and patient needs, varied disciplines bring their expertise to bear.

The ever-evolving pattern of care for coronary events mandates comparable changes and increased diversity in the delivery of rehabilitative care. Planning for rehabilitative care begins with the diagnosis of coronary disease or during hospitalization for an acute coronary event such as acute myocardial infarction, CABG, or PTCA. The short hospital stay for patients with uncomplicated myocardial infarction and after PTCA has necessitated accelerated in-hospital early ambulation and an abbreviated educational program, deferring a program of teaching to a later date once the patient has been discharged from the hospital. This structured outpatient multifactorial program of exercise training and coronary risk factor counseling and education is typically initiated within 1-3 weeks after hospital discharge. It provides supervision and, when medically appropriate, ECG monitoring of exercise training; education, counseling, and psychological services; and psychiatric therapy and vocational services when indicated. The duration of these components varies, depending on specific patient needs, from a minimum of 4-6 weeks to 6 months or more. This was traditionally called a Phase II program. Once patients attain initial goals, rehabilitation is continued in a maintenance program, with or without formal supervision or monitoring, traditionally known as a Phase III program.

Patients with complications of myocardial infarction, including recurrent symptomatic ischemia, ventricular dysfunction, or serious arrhythmias, have a prolonged hospital stay, require more supervision and gradual increases in ambulation, and need supplementary education and counseling, often including work assessment and vocational counseling. Patients of young to middle age who undergo elective myocardial revascularization with CABG or PTCA often undergo rapid ambulation and have a short hospital stay; these patients, who often have had the opportunity for preprocedure rehabilitative education and counseling, constitute an increased percentage of patients referred for outpatient cardiac rehabilitation. These and other low- and moderate-risk coronary patients are excellent candidates for early initiation of exercise training and prompt return to prior levels of activity, including return to work. More protracted guidance is warranted for coronary risk factor reduction (DeBusk, Houston Miller, Superko, et al., 1994; Haskell, Alderman, Fair, et al., 1994). Patients following successful PTCA (approximately 362,000 annually) are usually asymptomatic and have good residual ventricular function, good functional status, and brief hospital stays; they also have less early disability than do patients following CABG (Raft, McKee, Popio, et al., 1985). These patients have excellent potential for early exercise rehabilitation and return to work. Their potential for restenosis is high, however, up to 50 percent in the 6 months following successful PTCA (RITA Trial Participants, 1993). Because these patients rarely perceive their illness to be significant or appreciate their need for secondary preventive therapies, most require considerable guidance for coronary and psychosocial risk factor (e.g., depression, social isolation) reduction (Ben-Ari, Rothbaum, Linnemeir, et al., 1989). Their short hospitalization often limits both the provision of instruction and the skill building required to initiate behavioral changes for specific coronary risk reduction, requiring particular attention to this problem in the ambulatory care phase.

Patients with stable angina pectoris without recent myocardial infarction, almost one-fourth of the total coronary population, usually do not receive the benefits of structured cardiac rehabilitative care, commonly owing to the lack of insurance reimbursement. These patients often have substantial reduction in their quality of life and productivity because of ongoing symptoms, and their need for comprehensive medical surveillance and management may exceed that of patients after uncomplicated myocardial infarction. Rehabilitation services are uniquely suited for this patient group. Patients with stable angina are at risk for progression of the underlying coronary disease, including the development of unstable angina, myocardial infarction, heart failure, and arrhythmias (Fuster, Badimon, Badimon, et al., 1992).

Although many physicians report that they consider exercise training a component of care for coronary patients (Wenger, Hellerstein, Blackburn, et al., 1982), most patients following acute coronary events (myocardial infarction or revascularization) are not referred to formal supervised cardiac rehabilitation programs in the posthospital phase (Leon, Certo, Comoss, et al., 1990).

The focus of most published controlled clinical trials of exercise training has been the reduction of coronary morbidity and mortality. Most clinical trial data on the effects of cardiac rehabilitation on morbidity and mortality, however, predate contemporary life-saving therapies for acute myocardial infarction (Hamalainen, Luurila, Kallio, et al., 1989; Hedback, Perk, and Wodlin, 1993; Kallio, Hamalainen, Hakkilo, et al., 1979; Roman, Gutierrez, Luksic, et al., 1983; Vermeulen, Lie, and Durrer, 1983). These therapies include coronary thrombolysis and acute coronary angioplasty and the frequent use of elective myocardial revascularization procedures and newer pharmacologic therapies. Therefore, the risk and functional status of current-day patients may vary considerably. Four randomized controlled trials (in five reports) demonstrated a reduction in total mortality, coronary mortality, or both, favoring multifactorial rehabilitation versus control patients (Carson, Phillips, Lloyd, et al., 1982; Hamalainen, Luurila, Kallio, et al., 1989; Kallio, Hamalainen, Hakkilo, et al., 1979; Lamm, Denolin, Dorossiev, et al., 1982; P.R.E. Cor Group, 1991). Meta-analysis of pooled data from large prospective randomized exercise trials suggests as much as a 25 percent survival for exercising patients in the initial years following myocardial infarction (O'Connor, Buring, Yusuf, et al., 1989; Oldridge, Guyatt, Fischer, et al., 1988). Most of these trials included both coronary risk factor modification and exercise training. Randomized controlled trials reporting reinfarction rates following myocardial infarction did not establish a reduction in reinfarction favoring rehabilitation versus control patients. However, no excess rate of reinfarction occurred in the rehabilitation patient groups.

How do these observations apply to contemporary coronary care? Contemporary care has decreased early acute coronary mortality such that exercise training, as an isolated intervention, may not further significantly reduce short-term morbidity and mortality. However, exercise training is often considered the mechanism for facilitating other aspects of cardiac rehabilitation, including coronary risk reduction and optimization of psychosocial support. Thus it appears reasonable to evaluate quality-of-life attributes as outcome measures of rehabilitation ( Oldridge, 1991). Among these quality-of-life considerations are the patient's perception of physical improvement (compared with objectively measured functional capacity); satisfaction with favorable modifications of coronary risk; psychosocial adjustments in family and interpersonal roles; and potential for promotion and advancement at work -- the level of pay, the job prestige, and the extent to which the resumed work is commensurate with the patient's knowledge, skills, and abilities (rather than simply the return to work). Among elderly and more impaired patients, quality-of-life considerations include the facilitation of functional independence, prevention of premature disability, and postponement or lessening of the need for custodial care. Following rehabilitative care, patients are often less symptomatic and can return to work, leisure, and recreational activities (Dennis, Houston-Miller, Schwartz, et al., 1988; Lamm, Denolin, Dorossiev, et al., 1982; Mayou, MacMahon, Sleight, et al., 1981; Schiller and Baker, 1976). Rehabilitative care can help maintain independence for more impaired coronary patients, including many elderly ones ( Ades and Grunvald, 1990; Ades, Hanson, Gunther, et al., 1987; Ades, Waldmann, and Gillespie, 1995; Lavie, Milani, and Littman, 1993; Williams, Maresh, Esterbrooks, et al., 1985).

Older patients of both genders, in observational studies, improved their exercise tolerance comparably to younger patients participating in similar exercise training regimens (Ades, Hanson, Gunther, et al., 1987; Lavie, Milani, and Littman, 1993; Williams, Maresh, Esterbrooks, et al., 1985). Because data are limited for elderly patients and women, well-designed and well-executed studies involving older patients and women of all ages are needed.

## Changes in the Contemporary Approach to Exercise Training

Until recently, patients were traditionally advised to exercise to a target heart rate range between 70 and 85 percent of the highest level safely achieved at exercise testing (Haskell, 1978). However, exercise training intensities in the 50-70 percent heart rate range have been shown to effect comparable improvement in functional capacity and endurance, may provide greater safety during unsupervised exercise, and are likely to promote long-term adherence to exercise (Blumenthal, Rejeski, Walsh-Riddle, et al., 1988; Goble, Hare, Macdonald, et al., 1991; Rechnitzer, Cunningham, Andrew, et al., 1983). Lower intensity exercise training also increases both the applicability to and the acceptance of exercise training by larger numbers of coronary patients, particularly unfit and elderly patients and those with low exercise capacities (Blumenthal, Rejeski, Walsh-Riddle, et al., 1988; Goble, Hare, Macdonald, et al., 1991).

For many low-risk coronary patients, particularly those following myocardial revascularization procedures, rehabilitation often begins shortly after discharge from the hospital; many enter immediately what has traditionally been considered a Phase III program, that is, without intervening supervision in a Phase II component (DeBusk, Houston, Haskell, et al., 1979; DeBusk, Houston Miller, Superko, et al., 1994; Haskell, Alderman, Fair, et al., 1994). Approximately 70 percent of current survivors of myocardial infarction under age 70 years and many patients following uncomplicated myocardial revascularization procedures are at low risk for proximate cardiovascular events following discharge from the hospital (free of myocardial ischemia at exercise testing, significant ventricular arrhythmia, and/or significant left ventricular systolic dysfunction) (DeBusk, Houston Miller, Superko, et al., 1994). For these carefully selected low-risk patients, both medically directed home exercise and supervised exercise training have resulted in comparable improvements in functional capacity, without reported complications of home exercise training (DeBusk, Haskell, Miller, et al., 1985; Stevens and Hanson, 1984). These alternate approaches (home-based programs) to rehabilitative care include planned communication and management by rehabilitation nurses and other specially trained personnel (DeBusk, Houston Miller, Superko, et al., 1994; Haskell, Alderman, Fair, et al., 1994).

At the opposite end of the disease severity spectrum are elderly coronary patients; those with significant comorbidity; high-risk patients with continuing ischemia, compensated heart failure, or serious arrhythmias; those with complications of myocardial infarction or CABG; and those with severe angina pectoris. These patients may require closer surveillance of their exercise training for extended time periods (American College of Physicians, 1988; American Heart Association, 1990; Parmley, 1986). The requirements, duration, and complexity of exercise surveillance are based on the patient's clinical and risk factor status, as well as the patient's needs for exercise training.

In the early years of exercise rehabilitation, few patients had continuous ECG monitoring because ECG telemetry was not widely available. Programs with continuous ECG monitoring reported lower complication rates (Haskell, 1978 ), but it was unknown whether the ECG monitoring, the closer medical supervision, and/or the differences in exercise intensity were the safety determinants. More recently, continuous ECG monitoring of low-risk coronary patients was not shown to provide added safety during supervised exercise (Fagan, Wayne, and McConachy, 1984; Van Camp and Peterson, 1986). ECG monitoring is currently generally recommended only for high-risk patients and selected patients who have problems in exercising (American College of Physicians, 1988; DeBusk, Blomqvist, Kouchoukos, et al., 1986; Parmley, 1986; Wenger, 1992; World Health Organization Expert Committee, 1993). More extensive ECG monitoring is recommended by others (American Heart Association, 1990).

Recent data attest to the efficacy of concomitant risk reduction and long-term compliance with home-based exercise training, using periodic transtelephonic ECG monitoring and specialized cardiac nurse-management approaches, as well as with periodic clinic assessments (DeBusk, Houston Miller, Superko, et al., 1994; Fletcher, Dunbar, Felner, et al., 1994; Haskell, Alderman, Fair, et al., 1994). Long-term compliance with unsupervised exercise training and implementation of risk reduction in the absence of these management strategies is not known. Although some reports describe a greater magnitude and earlier improvement in physical work capacity with supervised exercise training, all training regimens increased functional capacity more than "spontaneous activity" in a variety of coronary patients (Coats, Adamopoulos, Meyer, et al., 1990; DeBusk, Haskell, Miller, et al., 1985; Haskell, Alderman, Fair, et al., 1994; Hung, McKillip, Savin, et al., 1982; Meyer, Casadei, Coats, et al., 1991; Taylor, Houston-Miller, Ahn, et al., 1986). Because economic constraints and logistics often limit the availability of supervised exercise training, the safety and effectiveness of unsupervised rehabilitative physical activity must be determined in various populations of coronary patients. Patients with prior exercise experience and those with family and social support are more likely to adhere to unsupervised exercise; cigarette smokers, overweight patients, blue-collar workers, those with sedentary occupations and low leisure-time activities, and patients who perceive their health status to be poor are less likely to do so (Oldridge, 1991 ). These patients should be encouraged to participate in structured cardiac rehabilitation programs.

Recent studies have shown that mild-to-moderate resistive exercise training can safely and effectively improve both strength and cardiovascular endurance in low-risk coronary patients who can perform adequate levels of aerobic exercise (Kelemen, 1989; Sparling, Cantwell, Dolan, et al., 1990; Stewart, Mason, and Keleman, 1988; Wilke, Sheldahl, Levandoski, et al., 1991). This approach to exercise training can improve performance in a variety of tasks of daily living, in the workplace, and at leisure activities. Resistance training provides diversity in the exercise regimen and may increase patient interest and adherence.

## Increased Scope of Patients Eligible for Exercise Rehabilitation

In the early years of exercise rehabilitation, this modality was considered suitable predominantly for patients recovering from uncomplicated myocardial infarction (Bengtsson, 1983; Carson, Phillips, Lloyd, et al., 1982; DeBusk, Houston, Haskell, et al., 1979; Hung, Gordon, Houston, et al., 1984; Hung, McKillip, Savin, et al., 1982; Kallio, Hamalainen, Hakkila, et al., 1979; Rechnitzner, Cunningham, Andrew, et al., 1983; Vermeulen, Lie, and Durrer, 1983; Wilhelmsen, Sanne, Elmfeldt, et al., 1975). Many categories of patients who, in prior years, were arbitrarily excluded from exercise rehabilitation, now constitute a large percentage of the enrollees in structured exercise rehabilitation programs. These include elderly coronary patients (Ades and Grunvald, 1990; Ades, Hanson, Gunther, et al., 1987; Ades, Huang, and Weaver, 1992; Ades, Waldmann, and Gillespie, 1995; Lavie, Milani, and Littman, 1993; Williams, Maresh, Esterbrooks, et al., 1985); high-risk coronary patients with combinations of myocardial ischemia, arrhythmia, or compensated heart failure (Giannuzzi, Temporelli, Tavazzi, et al., 1992; Grodzinski, Jette, Blumchen, et al., 1987; Meyer, Casadei, Coats, et al., 1991); and a variety of other medically complex patients (Arvan, 1988; Ehrman, Keteyian, Fedel, et al., 1992; Hertzeanu, Shemesh, Aron, et al., 1993; Kavanagh, Yacoub, Mertens, et al., 1988, 1989; Kellermann, Shemesh, Fisman, et al., 1990; Keteyian, Ehrman, Fedel, et al., 1990; Lee, Ice, Blessey, et al., 1979; Niset, Coustry-Degre, and Degre, 1988; Sullivan, Higginbotham, and Cobb, 1988). This limits the applicability of earlier data to contemporary cardiac rehabilitation. Exercise regimens for these latter patients are characterized by lower intensity, longer duration, and often an initial requirement for supervision and ECG monitoring. The goal of exercise for these latter categories of patients is typically an improvement in functional status so as to enable maintenance of independent living, in contrast to the goal of improvement of functional capacity to permit a return to remunerative work, which is frequently the desired outcome for younger and less impaired coronary patients.

## Return to Work

CHD is the leading diagnosis in the United States for which patients receive premature disability benefits under the Social Security system. Almost one-fourth of the men and women receiving Social Security disability allowances are considered permanently disabled by CHD (Wenger, 1987).

More than 750,000 patients under 65 years of age currently survive myocardial infarction or myocardial revascularization in the United States each year. The indirect health care costs of disability, including lessened productivity, loss of income, welfare payments, and unemployment insurance costs, must be considered when the cost-effectiveness of rehabilitative interventions is ascertained (Picard, Dennis, Schwartz, et al., 1989). Symptomatic and functional improvement in survivors of myocardial infarction and myocardial revascularization procedures correlate poorly with return to work and general resumption of preillness lifestyle; psychosocial status appears to be a more important determinant (Walter, 1985). Because only about 15 percent (and the percentage decreases with older age) of the U.S. labor force currently performs heavy manual labor, the severity of angina or heart failure in patients with marginal residual cardiac function only rarely precludes or delays the return to work. Most studies of return to work involved predominantly or exclusively men, but one report identified working women with CHD as having a longer convalescence and a lower rate of return to work (Walling, Tremblay, Jobin, et al., 1988); whether this is gender related or reflects the older age or occurrence of comorbid illnesses and depression among women warrants further study.

## Education, Counseling, and Behavioral Interventions

Education, counseling, and behavioral interventions are important elements of cardiac rehabilitation. In this guideline, "education" is defined as systematic instruction, and "counseling" is defined as providing advice, support, and consultation. "Behavioral interventions" refer to systematic instruction in techniques to modify health-related behaviors. Patients with cardiovascular disease have to learn to manage their illness and prevent or retard progression or induce regression of atherosclerosis. This management focuses on techniques of lifestyle changes, guided by health professionals. Approaches to teach patients effective health management techniques (Bilodeau and Hackett, 1971; Cowan, 1990; Dracup, 1985; Dunbar, Marshall, and Novell, 1979; Foley, Sivarajan, and Woods, 1983; Godin, 1989; Hentinen, 1983; Houston Miller, Taylor, Davidson, et al., 1990; Kinney and Packa, 1988; Lindskog and Sivarajan, 1982; Miller, 1985; Miller, Haskell, Berra, et al., 1984; Newton, Sivarajan, Bruce, et al., 1981; Ott, Sivarajan, Newton, et al., 1983; Scalzi, Burke, and Greenland, 1980; Sikorski, 1985; Sivarajan, Bruce, Almes, et al., 1981; Sivarajan and Newton, 1984; Sivarajan, Newton, Almes, et al., 1983; Sivarajan, Snydsman, Smith, et al., 1977; Sivarajan Froelicher, 1988; Sivarajan Froelicher and Perdue, 1991; Taylor, Bandura, Ewart, et al., 1985; Taylor, Houston-Miller, Haskell, et al., 1988; Woods, Sivarajan Froelicher, Halpenny, et al., 1994) and the effectiveness of the educational messages (Godin, 1989; Miller, 1985; Newton, Sivarajan, and Clarke, 1985) have been based on educational models. Some studies used principles of education, counseling ( Yalom, 1975), and behavioral psychology as interventions; most studies were unable to separate these elements in patient education. Because of the substantial morbidity and mortality of CHD and the role of behavior in rehabilitation, patient education is an integral part of cardiac rehabilitative care. The conclusions of a meta-analysis of 28 controlled trials of patient education were that "education programs have demonstrated a measurable impact on blood pressure, mortality, exercise, diet, and other parameters are positively affected, although less consistently" (Mullen, Mains, Velez, et al., 1992). Type of communication did not influence outcome; adherence to educational principles did. Thus, cardiac rehabilitation programs should use reinforcement, provide feedback, offer opportunity for individualization, facilitate behavioral change through the development of skills and resources, and be relevant to patients' needs and abilities. Education alone does not change behavior, although it can reduce anxiety and alleviate depression (Godin, 1989; Houston Miller, Taylor, Davidson, et al., 1990). A combination of education, counseling, and behavioral intervention strategies seems most effective in promoting health, reducing risk, and favorably altering lifestyle (Miller, Haskell, Berra, et al., 1984; Newton, Sivarajan, Bruce, et al., 1981; Newton, Sivarajan, and Clarke, 1985). Specific behavioral interventions using social learning theory have been advocated ( Blumenthal, Califf, Williams, et al., 1983; Newton, Sivarajan, and Clarke, 1985; Taylor, Bandura, Ewart, et al., 1985; Taylor, Houston-Miller, Haskell, et al., 1988).

Whether the same approaches in patient education, counseling, and behavioral interventions are equally effective for men and women and across the age span remains unanswered because most studies enrolled middle-aged men. Minimal information on patients 70 years and older is available (Hawe and Higgins, 1990; King, Haskell, Taylor, et al., 1991), and few studies included women (Foley, Sivarajan, and Woods, 1983; Ott, Sivarajan, Newton, et al., 1983; Sivarajan, Newton, Almes, et al., 1983).

Most early studies of education involved patients recovering from myocardial infarction and focused on the ideal content for an education program (Foley, Sivarajan, and Woods, 1983; Godin, 1989; Houston Miller, Taylor, Davidson, et al., 1990; Miller, Haskell, Berra, et al., 1984; Newton, Sivarajan, and Clarke, 1985; Ott, Sivarajan, Newton, et al., 1983; Scalzi, Burke, and Greenland, 1980; Sivarajan, Bruce, Almes, et al., 1981; Sivarajan, Newton, Almes, et al., 1983; Sivarajan Froelicher, 1988). These studies took place in the hospital; later studies focused on education after hospital discharge, pertinent to contemporary practice where early discharge limits or obviates comprehensive hospital-based education, counseling, or behavioral interventions. Educational programs were subsequently extended to patients following CABG, PTCA, cardiac transplantation, and valve surgery. Educational needs and outcomes depend on the specific cardiovascular disease and intervention. Definitive studies are lacking that address educational needs and opportunities for patients with advanced cardiac problems such as heart failure, including those awaiting cardiac transplantation.

Studies of educational programs in the outpatient setting are few and not well described. The home education (Miller, Haskell, Berra, et al., 1984; Sivarajan, Newton, Almes, et al., 1983) delivered either via telephone or visits by public health nurses and/or physicians is a model more common in the United Kingdom. Combinations of these approaches (e.g., weekly outpatient clinic appointments plus telephone followup) are becoming more common (Miller, Haskell, Berra, et al., 1984; Ott, Sivarajan, Newton, et al., 1983). Other forms of home-based educational programs such as the visiting nurse service have not been fully utilized in the United States. These approaches warrant further investigation, especially as the population ages.

Most education about the disease and treatment is provided by physicians, nurses, physical therapists, exercise physiologists, and dietitians. (Some scientific reports use the terms "dietitian" and "nutritionist" interchangeably; this guideline uses "dietitian.") Other health professionals play a role in providing specific health education interventions in the patient's care and knowledge of disease, treatment, adjustment to illness, and expected outcomes.

The focus of education in the reported studies was the patient, the couple (such as the patient and spouse or partner) (Dracup, 1985; Hentinen, 1983; Taylor, Bandura, Ewart, et al., 1985), and groups of patients ( Newton, Sivarajan, and Clarke, 1985; Oldridge, 1991; Sivarajan and Newton, 1984; Sivarajan, Newton, Almes, et al., 1983). The interventions included smoking cessation and relapse prevention (Sallis, Flora, Fortmann, et al., 1985; Taylor, Houston-Miller, Haskell, et al., 1988); ambulation and activity progression ( Miller, Haskell, Berra, et al., 1984; Sivarajan, Bruce, Almes, et al., 1981); energy conservation (particularly important in patients with advanced heart disease) (Sivarajan, Bruce, Almes, et al., 1981); exercise prescription (Lindskog and Sivarajan, 1982; Miller, Haskell, Berra, et al., 1984; Sivarajan, Snydsman, Smith, et 1977); resumption of sexual activity (Froelicher, Kee, Newton, et al., 1994); and return to work (Froelicher, Kee, Newton, et al.,1994; Sivarajan, Newton, Almes, et al.,1983). Dietary interventions included management of diet and medication to control hypertension and hyperlipidemia ( Newton, Sivarajan, and Clarke, 1985; Sivarajan and Newton, 1984; Sivarajan, Newton, Almes, et al., 1983). The extent of adherence to medication regimens has been extensively reported in the adherence literature (Blumenthal, Califf, Williams, et al., 1983; Dunbar, Marshall, and Novell, 1979; Godin, 1989; King, Haskell, Taylor, et al., 1991; Kinney and Packa, 1988). This literature also addresses adherence to exercise training interventions (King, Haskell, Taylor, et al., 1991).

## Psychosocial Aspects

The importance of psychosocial variables in the development of CHD and in the prognosis of patients with established CHD has received increased attention during the past decade. In particular, Type-A behavior pattern and hostility, depression, vital exhaustion, social isolation, and lack of social resources have been identified as important targets for education, counseling, and behavioral interventions.

### Type-A Behavior Pattern and Hostility

Type-A behavior pattern has received more attention than any other behavioral or psychological variable as a risk factor for CHD. Individuals who exhibit Type-A behavior pattern display a variety of traits and behavioral dispositions, including hard-driving competitiveness, a persistent sense of time urgency, and easily evoked hostility. A relative absence of these behavioral features characterizes the converse, Type-B behavior pattern. In 1981, a review panel assembled by NHLBI concluded that Type-A behavior pattern is an independent risk factor for CHD in employed, middle-aged U.S. citizens (Review Panel on Coronary-Prone Behavior and Coronary Heart Disease, 1981). This conclusion was based on a number of studies investigating the development of CHD in healthy persons, as well as studies of patients with documented CHD, prior myocardial infarction, or cardiac risk factors.

Type-A men in the Western Collaborative Group Study (WCGS) were five times more likely to have had a recurrent myocardial infarction compared with Type-B men. This strong association was significant even after considering the contribution of elevated levels of cholesterol, blood pressure, and cigarette smoking (Rosenman, Brand, Jenkins, et al., 1975). However, subsequent studies failed to support these findings (Case, Heller, Case, et al., 1985 ; Shekelle, Gale, Norusis, et al., 1985; Shekelle, Hulley, Neaton, et al., 1985).

One explanation for inconsistent findings related to Type-A behavior and CHD is that global Type-A measures are too broad and nonspecific to identify the components of Type-A behavior pattern relevant to CHD events. Just as not all components of cholesterol are detrimental, and indeed, some components are beneficial (e.g., the high-density lipoprotein [HDL] fraction), the hostility component of Type-A behavior pattern currently is regarded as the most "toxic" component. Evidence is accumulating that high levels of anger and hostility are associated with CHD and other adverse health outcomes. One instrument that has been used to measure hostility -- the Cook Medley Hostility Scale (derived from the Minnesota Multiphasic Personality Inventory [MMPI]) -- has shown hostility to be related to the extent of CHD in coronary patients (Matthews, Glass, Rosenman, et al., 1977; Williams, Barefoot, Haney, et al., 1988), and prospectively to an increased risk of cardiac morbidity and all cause mortality in nonclinical populations (Barefoot, Dahlstrom, and Williams, 1983; Shekelle, Gale, Ostfeld, et al., 1983). More myocardial ischemia was observed in women and middle-aged men with CHD who had high hostility scores than in those with low scores (Helmers, Krantz, Howell, et al., 1993).

### Depression

Depression is reported to precede myocardial infarction in 33-50 percent of patients. Higher rates of myocardial infarction have been reported among depressed than nondepressed psychiatric patients. Examination of 283 hospitalized patients with myocardial infarction showed that 18 percent had major depression and an additional 27 percent had symptoms of depression (Schleifer, Macari-Hinson, Coyle, et al., 1989). Depression is associated with increased mortality and medical morbidity after myocardial infarction and cardiac surgery (Ahern, Gorkin, Anderson, et al., 1990; Frasure-Smith, Lesperance, and Talajic, 1993; Garrity and Klein, 1975; Kimball, 1969; Stern, Pascale, and Ackerman, 1977).

In a recent study, patients who met the modified Diagnostic and Statistical Manual for Mental Disorders (DSM-III-R; American Psychiatric Association, 1987) criteria for major depressive disorder (16 percent of the sample of 272 patients) were more than five times more likely to die during the first 6 months following myocardial infarction than nondepressed patients (Frasure-Smith, Lesperance, and Talajic, 1993). The effect of depression was independent of Killip class, ejection fraction, and other clinical indicators of disease severity. Depressive affect short of major depressive disorder also conferred higher risk in this population (Frasure-Smith, Lesperance, and Talajic, 1995).

Another factor possibly related to depression is a constellation of symptoms known as "vital exhaustion." Vital exhaustion is characterized by excessive fatigue, decreased energy, feelings of dejection or defeat, loss of libido, and increased irritability. The proportion of individuals experiencing this syndrome prior to a coronary event has been estimated at 30-50 percent.

Several studies investigating the association of vital exhaustion and CHD found it to be positively associated with stable and unstable angina pectoris (Appels, 1980; Appels, 1990; Appels and Mulder, 1988; Appels and Mulder, 1989). Vital exhaustion was also associated with future angina pectoris and nonfatal myocardial infarction (but not with fatal myocardial infarction) and with an increased risk of coronary events following PTCA (Kop, Appels, Mendes de Leon, et al., 1994).

### Social Isolation and Low Socioeconomic Status

The prognostic value of level of education and psychosocial characteristics (life stress, social isolation, Type-A behavior, depression) was studied in male patients after myocardial infarction (Appels, 1990). Depression may be associated with social isolation, which may serve as an independent risk factor. For example, a 6-month mortality of 15.8 percent occurred among patients after myocardial infarction living alone (16.4 percent of total sample) versus 8.8 percent among those living with others. In a followup study of patients with angiographically documented coronary disease, a 50-percent 5-year mortality rate occurred among those who were most socially isolated (unmarried with no confidant, 26 percent of total sample) versus 17 percent among those not so isolated (Appels, 1990). In both studies, the impact of social isolation on prognosis was independent of left ventricular ejection fraction and other physiologic prognostic factors.

## Summary

The challenge in the 21st century is to select, develop, and provide appropriate rehabilitative services for an individual cardiac patient and to tailor the method of delivery of these services. The selection strategy should incorporate both health care provider recommendations and patient preferences and should be designed to facilitate progressive independence in cardiac rehabilitation and long-term comprehensive care. This concept should be attractive to patients, to their health care providers, and to those responsible for the costs of rehabilitative cardiac care.

The decision tree (Figure 1) provides a summary of the highlights of cardiac rehabilitation. The decision tree is divided into three components: patient categories; assessment and individualization of the treatment plan for exercise training; and assessment and individualization of the treatment plan for risk factor modification and psychosocial status. Under each component of the decision tree, information is presented in diamonds or rectangles. Diamonds represent yes-no decision points; rectangles represent intervention strategies or other clinical decisionmaking by the provider of cardiac rehabilitation services.

Figure 1. Decision tree for cardiac rehabilitation services—Patient Categories

Cardiac rehabilitation intervention is a multifactorial process. Therefore, even though the decision tree separates the treatment plan into exercise training and other important components of management for patients participating in cardiac rehabilitation, the optimal outcomes are achieved when the rehabilitative strategies are combined. Each point summarized in the decision tree is fully explained in this guideline. The decision tree serves as a pathway for the clinician to address patient categories and aspects of assessment and treatment.

## Methodology

In 1992, AHCPR awarded a contract for the development of this Clinical Practice Guideline to AACVPR. The project was cosponsored by NHLBI. Based on nominations solicited by a Federal Register notice, AACVPR recommended a multidisciplinary panel of health care providers and consumers to assist in developing the Clinical Practice Guideline, and the panel members were approved by AHCPR. The panel members represent a diversity of health care specialties that include clinical and academic perspectives: cardiology, internal medicine, family medicine, nursing, behavioral science, dietetics, physical therapy, and exercise physiology, as well as the consumer perspective.

The initial task of the panel was to structure an analytical framework to guide the search and review of the scientific literature. The key components of this framework included choice of patient populations and types of cardiac rehabilitative interventions and outcomes. On the basis of the proportion of patients with major categories of cardiovascular diseases, the panel identified as the target populations for this guideline (1) patients with manifestations of CHD, including stable angina pectoris, silent ischemia, acute myocardial infarction, and those undergoing myocardial revascularization with CABG and PTCA, and (2) the increasing number of patients with heart failure, including patients awaiting or following cardiac transplantation.

The components of cardiac rehabilitation services were defined as exercise training; education, counseling, and behavioral interventions; intake assessment; risk stratification; adherence; and cost. Each of these components of cardiac rehabilitation, in turn, was defined and described.

The panel identified the outcomes (both beneficial and potentially harmful) resulting from the components of cardiac rehabilitation. The outcomes were further classified as intermediate outcomes or health outcomes. Intermediate outcomes are measurable physiologic changes resulting from the components of cardiac rehabilitation. Examples of intermediate outcomes include changes in lipid or lipoprotein values, exercise tolerance as measured by exercise testing, and other pathophysiologic measures such as changes in myocardial perfusion, ventricular performance, or coronary artery diameter as an indicator of regression or progression of coronary atherosclerosis. In contrast, health outcomes are those experienced or reported by patients; these can be beneficial or harmful. Examples of beneficial health outcomes include improvement in exercise tolerance, reduction in cardiovascular symptoms, reduction in cardiovascular morbidity or mortality, and reduction in total mortality. Improvement in psychosocial function, measures of independence, and rates of return to work are additional beneficial health outcomes potentially resulting from cardiac rehabilitation. Harmful health outcomes potentially resulting from cardiac rehabilitation include increases in cardiovascular morbidity, cardiovascular mortality, or total mortality or adverse changes in psychosocial status such as an increase in anxiety or depression.

The methodology that was used to develop this Clinical Practice Guideline mandated a well-documented review of all scientific evidence relevant to cardiac rehabilitation. Search of the scientific literature was conducted for original reports that met criteria for admissible evidence. These criteria included publication subsequent to 1966, availability of the full scientific paper in English, and original scientific work presented in full in peer-reviewed journals. Abstracts were not included for review. Review articles, as well as position papers and other summary statements from relevant professional and governmental organizations, served as sources for supporting information and other resource functions (when used, these are clearly indicated in the guideline).

The data sources for review of the scientific literature included: (1) the National Library of Medicine (MEDLARS) through an electronic-based software system (Grateful Med); (2) PsycINFO, ERIC, and CINAHL databases; and (3) review of potentially appropriate scientific publications not indexed in these databases, with special emphasis on the psychosocial and professional nursing literature. In addition, recognized national and international experts in cardiac rehabilitation were solicited to provide the panel with appropriate literature citations to consider for review.

The panel established criteria for inclusion or exclusion of an individual report for further review and its potential use as a source of evidence for the guideline recommendations. Relevant literature was defined as reports of research studies addressing the patient populations, elements of cardiac rehabilitation, and outcomes identified in the analytic framework. Reports were excluded that (1) did not specify the selected cardiovascular diseases, (2) involved interventions without defined elements of cardiac rehabilitation, or (3) addressed outcomes other than those selected. All study interventions had to be provided in a rehabilitation framework to be considered for inclusion.

Almost 900 scientific reports were examined; approximately 500 were determined not relevant on the basis of the just-mentioned criteria. Over 400 reports were critically reviewed, and 334 are included as references in this Clinical Practice Guideline. The review process focused on the elements of cardiac rehabilitation as specific interventions. Frequently, multiple interventions were undertaken concomitantly in a given research study. In such cases, more than one panel member reviewed the research report, with special emphasis on the intervention component related to that individual's expertise and interest. The scientific reports were further analyzed for the outcome(s) reported. Careful attention was directed to identify and evaluate harms reported to result from cardiac rehabilitation services.

The hierarchy of study design and conduct was established prior to review of the scientific literature. A randomized controlled study design potentially presents the most scientifically rigorous information. However, a poorly designed or poorly executed randomized controlled trial may have less reliable data than a well-designed and well-executed nonrandomized but controlled study, if patients are well matched. The review of each scientific report resulted in an overall rating by the panel member as to study quality. The greatest weight of evidence was accorded to well-designed and well-executed randomized controlled trials, and the least weight was given to observational studies. The panel also considered the scientific rigor with which the study was carried out in weighing the evidence. Specific attention was paid to the generalizability of published results. Studies excluding patients by clinical criteria (e.g., patients with heart failure or high-risk patients), thus enrolling a restricted group of patients, or by demographic variables (e.g., age, gender) were highlighted. Many of the randomized controlled trials that were reviewed were initiated and conducted prior to the application of contemporary, high-technology approaches to managing patients with cardiovascular diseases. For example, little information is available regarding outcomes of cardiac rehabilitation in patients following acute myocardial infarction treated with thrombolytic therapy, as well as coronary patients undergoing acute PTCA for acute myocardial infarction.

The organization of the literature review included an ongoing determination of intra- and interrater reliability. This was carried out by the panel co-chairs and the project director and included multiple reviews of the same scientific report by several panel members. In addition, a smaller writing group of panel members (panel co-chairs and subcommittee chairs), re-reviewed all selected reports prior to final review by the entire panel of all abstracted scientific evidence pertaining to each intervention as it related to each outcome.

The reports of scientific evidence addressing each cardiac rehabilitation intervention were reviewed as a group; were reached by the entire panel regarding the outcomes described to result from each intervention. When appropriate and necessary, expert opinion was formally derived from the panel to supplement or balance the conclusions reached from review of the scientific evidence. This Clinical Practice Guideline clearly identifies when expert opinion was used to substantiate a recommendation.

## Strength-of-Evidence Ratings

The panel assigned a letter grade, designating the strength of the scientific evidence, for each guideline recommendation. Ratings reflect both the quality of the studies, including study design and methods used, and the consistency of the results of the scientific evidence:

- A Scientific evidence provided by well-designed, well-conducted, controlled trials (randomized and nonrandomized) with statistically significant results that consistently support the guideline recommendation.
- B Scientific evidence provided by observational studies or by controlled trials with less consistent results to support the guideline recommendation.
- C Expert opinion that supports the guideline recommendation because the available scientific evidence did not present consistent results, or controlled trials were lacking.

The panel acknowledges that many important questions related to patient management decisions do not have a strong research basis. Therefore, the rating format does not necessarily reflect the importance of the guideline recommendation to patient care. This importance is conveyed through the use of careful wording in each guideline recommendation.

Meta-analyses were not commissioned in the development of this guideline. The panel decided that meta-analysis was not indicated because of the considerable differences in patient populations, study designs, intervention techniques, and lack of details in many reports. These problems challenge the validity of applying meta-analytical techniques to this database. Furthermore, cardiac rehabilitation interventions are multifactorial, and the interrelated effects of the interventions or elements make the contribution of each specific intervention to the outcome difficult to quantify. Finally, the pronounced temporal changes in both the acute and the long-term treatment of patients with CHD over the decades in which the cardiac rehabilitation studies were conducted provided additional justification not to use meta-analytical methods. Instead, a comparison of benefits and harms was undertaken for each intervention component of cardiac rehabilitation services, when the scientific evidence enabled such comparison.

Several draft versions of this guideline were reviewed by 41 health professionals to comply with the process of peer review. Peer review occurred on two separate occasions as the guideline was developed. The detailed comments of the peer reviewers were addressed by the panel and incorporated into the guideline.