# Attachments

The attachments consist of summary tables describing the preferred instruments. Clinicians desiring to use them with patients should use the referenced sources and obtain the actual assessments and accompanying instructions for administering and scoring purposes.

Recommended standardized assessment instruments for use with stroke patients

Attachment 1. Level-of-consciousness scale

Instrument | Description | Validity, reliability, and sensitivity | Uses and time to administer | Strengths and Weaknesses
Glasgow Coma Scale [a,b] | 3 sections scoring eye opening, motor, and verbal responses to voice commands or pain. Each section scored separately on scales ranging from 4 to 6 points. | Validity: Face and predictive validity well demonstrated. [b,c,**] Reliability: Interobserver reliability good. [d,**] Sensitivity: Reasonable [b,*] | Use: Acute post-stroke period. Time: 2 minutes. | Strengths: Simple, valid, reliable, and widely used.

[a] Teasdale and Jennett, 1974.

[b] Teasdale, Murray, Parker, et al., 1979.

[c] Levy, Bates, Caronna, et al., 1981.

[d] Teasdale, Knill-Jones, and Van der Sande, 1978.

Note: * = adequately evaluated. ** = comprehensively evaluated.

Attachment 2. Stroke deficit scales

Instrument | Description | Validity, reliability, and sensitivity | Uses and time to administer | Strengths and Weaknesses
NIH Stroke Scale [a] | 15 items scored on 3- or 4-point interval scales. Domains: Consciousness, vision, extraocular movements, facial palsy, limb strength, ataxia, sensation, speech and language. | Validity: Good correlation with infract volume and 3-month outcomes. [a,c,**] Reliability: Moderate interrater and intrarater reliability. [a,b,c,*] | Uses: Acute care, screening, formal assessment, monitoring. Time: 5 - 10 minutes. | Strengths: Brief. Good reliability. Can be administered by nonneurologists. Weaknesses: Interval scale is relatively insensitive to change.
Canadian Neurological Scale | 8 items scored on a 3-point interval scale. Score is 10 in normal patients. Separate section measures face and motor responses in cognitively impaired patients. Domains: Consciousness, orientation, speech, motor function, facial weakness. | Validity: Established versus neurological examination and Katz ADL scores. [e,*] Reliability: Moderate interrater and intrarater reliability. [e,*] | Uses: Acute care, screening, formal assessment, monitoring. Time: 5 minutes. | Strengths: Brief. Valid with good reliability. Weaknesses: Omits ataxia, visual fields, eye movements. Interval scale relatively insensitive to change.

[a] Brott, Adams, Olinger, et al., 1989.

[b] Goldstein, Bertels, and Davis, 1989.

[c] Wityk, Pessin, Kaplan, et al., 1994.

[d] Cote, Hachinski, Shurvell, et al., 1986.

[e] Cote, Battista, Wolfson, et al., 1989.

Note: * = adequately evaluated, ** = comprehensively evaluated. ADL = activities of daily living.

Attachment 3. Global disability scale

Instrument | Description | Validity, reliability, and sensitivity | Uses and time to administer | Strengths and Weaknesses
Rankin Scale[a] Scale Modification [b,c] | Ordinal scale with six grades indicating degrees of disability. | Validity [b,**] Reliability [c,*] Sensitivity: Not tested. | Uses: Acute hospitalization. Time: 5 minutes. | Strengths: Simple overall assessment of disability. Weaknesses: Walking the only explicit function assessed. Probably insensitive to change.

[a] Rankin, 1957.

[b] Bonita and Beaglehole, 1988.

[c] van Swieten, Koudstaal, Visser, et al., 1988.

Note: * = adequately evaluated, ** = comprehensively evaluated.

Attachment 4. Measures of disability in basic activities of daily living (ADL)

Instrument | Description | Validity, reliability, and sensitivity | Uses and time to administer | Strengths and Weaknesses
Barthel Index[a,b] | Ordinal scale with total scores from 0 (totally dependent) to 20 (totally independent) (or, 0 to 100 by multiplying each item score by 5). 10 items: bowels, bladder, feeding, grooming, dressing, transfer, toilet use, mobility, stairs, bathing. | Validity[c,d,e,f,**] Reliability[b,g,**] Sensitivity[c,f,h,i,j,**] | Uses: Screening, formal assessment, monitoring, maintenance. Time: 5-10 minutes. | Strengths: Widely used in stroke disability. Excellent reliability and validity. Weaknesses: "Ceiling" effect in detecting change at higher level functioning. Only fair sensitivity to change.
Functional Independence Measure (FIM)[k,l,m,n] | 18 items scored on a 7-point ordinal scale (1 = complete independence; 7 = total assistance). Total score ranges from 18 to 126. Subscores for motor function and cognition. Domains for self-care, sphincter control mobility, locomotion, communication, and social cognition. | Validity[o,p,**] Reliability[o,q,**] Sensitivity[o,r,**] | Uses: Screening, formal assessment, monitoring, maintenance. Time: < 40 minutes. | Strengths: Measures social cognition and functional communication as well as mobility and ADL. Use of 7-point scale increases sensitivity versus other disability scales. Widely used in the United States and other countries. Weaknesses: "Ceiling" and "floor" effects at the upper and lower ends of function.

[a] Mahoney and Barthel, 1965.

[b] Wade and Collin, 1988.

[c] Gresham, Phillips, and Labi, 1980.

[d] Wade and Hewer, 1987a.

[e] Hertanu, Demopoulos, Yang, et al., 1984.

[f] Duncan, 1992.

[g] Shinar, Gross, Bronstein, et al., 1987.

[h] Shah, Vanclay, and Cooper, 1989.

[i] Granger, Albrecht, and Hamilton, 1979.

[j] Granger, Dewis, Peters, et al., 1979.

[k] Guide for the uniform data set for medical rehabilitation, 1993.

[l] Granger, Hamilton, Keith, et al., 1986.

[m] Granger, Hamilton, and Sherwin, 1986.

[n] Keith, Granger, Hamilton, et al., 1987.

[o] Hamilton, Granger, Sherwin, et al., 1987.

[p] Granger and Hamilton, 1990.

[q] Hamilton, Laughlin, Granger, et al., 1991.

[r] Granger and Hamilton, 1992.

Note: * = adequately evaluated, ** = comprehensively evaluated, ADL = activities of daily living.

Additional useful instruments include the Katz Index of ADL (Katz, Ford, Moskowitz, et al., 1963), the Kenny Self-Care Evaluation (Schoening and Iversen,1968), LORS/LAD (Carey and Posavac,1978), and PECS (Harvey and Jellinek, 1981).

Attachment 5. Mental status screening tests

Instrument | Description | Validity, reliability, and sensitivity | Uses and time to administer | Strengths and Weaknesses
Mini-Mental State Examination (MMSE)[a] | 7 domains including orientation to time and place, registration of words, attention, calculation, recall, language, and visual construction. | Validity[a,b,*] Reliability[a,b,*] Sensitivity[b,c,d,*] | Uses: Screening. Time: < 10 minutes. | Strengths: Widely used for screening. Sensitive. Weaknesses: Several functions with summed score. May misclassify patients with aphasia. Education and normal aging must be considered in interpreting overall score.
Neurobehavioral Cognitive Status Examination (NCSE)[e,f] | 10 scales: Graded assessment of function. Domains: Orientation, attention, comprehension, naming, construction, memory, calculation, similarities, judgment, and repetition. | Validity[f,g,h,i,*] Reliability: Not tested in stroke patients. Sensitivity[i,*] | Uses: Screening. Time: < 30 minutes. | Strengths: Predicts gain in Barthel Index score. Unrelated to age. Weaknesses: Does not distinguish right from left hemisphere strokes. No reliability studies on stroke. No studies of factorial structure. Correlates with education.[h]

[a] Mahoney and Barthel, 1965.

[b] Wade and Collin, 1988.

[c] Gresham, Phillips, and Labi, 1980.

[d] Wade and Hewer, 1987a.

[e] Hertanu, Demopoulos, Yang, et al., 1984.

[f] Duncan, 1992.

[g] Shinar, Gross, Bronstein, et al., 1987.

[h] Shah, Vanclay, and Cooper, 1989.

[i] Granger, Albrecht, and Hamilton, 1979.

[j] Granger, Dewis, Peters, et al., 1979.

[k] Guide for the uniform data set for medical rehabilitation, 1993.

[l] Granger, Hamilton, Keith, et al., 1986.

[m] Granger, Hamilton, and Sherwin, 1986.

[n] Keith, Granger, Hamilton, et al., 1987.

[o] Hamilton, Granger, Sherwin, et al., 1987.

[p] Granger and Hamilton, 1990.

[q] Hamilton, Laughlin, Granger, et al., 1991.

[r] Granger and Hamilton, 1992.

Note: * = adequately evaluated, ** = comprehensively evaluated, ADL = activities of daily living.

Additional useful instruments include the Katz Index of ADL (Katz, Ford, Moskowitz, et al., 1963), the Kenny Self-Care Evaluation (Schoening and Iversen,1968), LORS/LAD (Carey and Posavac,1978), and PECS (Harvey and Jellinek, 1981).

Attachment 6. Assessment of motor function

Instrument | Description | Validity, reliability, and sensitivity | Uses and time to administer | Strengths and Weaknesses
Fugl-Meyer[a] | Measures impairment on a 3-point ordinal scale. Measurement of volitional movement is hierarchical. Sums are treated as continuous variables. Domains: Pain, range of motion, sensation, volitional movement, and balance. | Validity[a,b,c,d,e,**] Reliability[f,*] Sensitivity: Not formally tested but detected changes in cohorts of patients.[g] | Uses: Formal assessment, monitoring. Time: 30-40 minutes. | Strengths: Extensively evaluated measure. Good validity and reliability for assessing motor function and balance. Weaknesses: Many clinicians view the measure as too complex and time-consuming.
Motor Assessment Scale[h] | Measures impairment and disability on 6-point ordinal scale. Domains: Volitional arm and hand movements, tone, mobility (i.e., rolling, supine to sit, sitting, standing, walking). | Validity[i,*] Reliability[h,j,*] Sensitivity: Not tested. | Uses: Formal assessment, monitoring. Time: 15 minutes. | Strengths: Good reliability and validity. Weaknesses: Long to administer. Reliability assessed only in stable patients. Sensitivity to detect change not tested.
Motricity Index[k,l] | Measures impairment on a weighted ordinal scale. Domains: Strength and trunk control. | Validity[k,l,m,*] Reliability[l,*] Sensitivity: Not tested. | Uses: Screening, formal assessment, monitoring. Time: < 5 minutes. | Strengths: Brief assessment of motor function of arm, leg, and trunk. Weaknesses: Sensitivity to detect change not tested.

[a] Fugl-Meyer, Jaasko, Leyman, et al., 1975.

[b] Berglund and Fugl-Meyer, 1986.

[c] De Weerdt and Harrison, 1985.

[d] Wood-Dauphinee, Williams, and Shapiro, 1990.

[e] Dettmann, Linder, and Sepic, 1987.

[f] Duncan, Propst, and Nelson, 1983.

[g] Duncan, 1992.

[h] Carr, Shepherd, Nordholm, et al., 1985.

[i] Poole and Whitney, 1988.

[j] Loewen and Anderson, 1988.

[k] Demeurisse, Demol, and Robaye, 1980.

[l] Collin and Wade, 1990.

[m] Wade and Hewer, 1987a.

Note: * = adequately evaluated. ** = comprehensively evaluated.

Attachment 7. Balance assessment

Instrument | Description | Validity, reliability, and sensitivity | Uses and time to administer | Strengths and Weaknesses
Berg Balance Scale[a,][b] | Measures disability on 0-4 point ordinal scale. Domains: 14 items of balance. | Validity[a,][b,][**] Reliability[b,][**] Sensitivity[b,][*] | Uses: Formal assessment, monitoring. Time: < 10 minutes. | Strengths: Very simple measure of balance. Well characterized in stroke patients. Sensitive to change.

[a] Berg, Maki, Williams, et al., 1992.

[b] Berg, Wood-Dauphinee, Williams, et al., 1989.

Note: * = adequately evaluated. ** = comprehensively evaluated.

Attachment 8. Mobility assessment

Instrument | Description | Validity, reliability, and sensitivity | Uses and time to administer | Strengths and Weaknesses
Rivermead Mobility Index[a,b] | Measures disability on a pass/fail scale. Domains: Turning over in bed, sitting, standing, transferring, and walking. | Validity[a,*] Reliability[a,*] Sensitivity[b,*] | Uses: Screening, formal assessment, monitoring. Time: < 5 minutes. | Strengths: Brief test of physical mobility. Reliable and valid.

[a] Wade, Collen, Robb, et al., 1992.

[b] Collen, Wade, Robb, et al., 1991.

Note: * = adequately evaluated.

Attachment 9. Assessment of speech and language functions

Instrument | Description | Validity, reliability, and sensitivity | Uses and time to administer | Strengths and Weaknesses
Boston Diagnostic Aphasia Examination [a,b] | Assesses sample speech and language behavior on a 6-point ordinal scale. Modalities assessed: Fluency, naming, word finding, repetition, serial speech, auditory comprehension, reading, writing. Examiner judges grammar, syntax, frequency of paraphasias, and articulation. | Validity [b,*] Reliability: Not tested. Sensitivity: Not tested. | Uses: Formal assessment, monitoring. Time: 1-4 hours. | Strengths: Widely used, comprehensive, good standardization data, sound theoretical rationale.
Porch Index of Communicative Ability (PICA) [c] | Scored by a 16-point multidimensional scale with mean scores for entire test and each modality. Modalities assessed: Auditory comprehension, visual comprehension, written expression, verbal expression, and pantomime. | Validity: Standardized in 357 left, 96 right, and 100 bilateral hemisphere damaged subjects. [c,*] Reliability [c,*] Sensitivity: Not tested. | Uses: Formal assessment and monitoring. Time: 1/2-2 hours. | Strengths: Widely used, comprehensive, careful test development and standardization. Weaknesses: Requires special training to administer. Inadequate sampling of language other than one word and single sentences.
Western Aphasia Battery [d] | "Aphasia Quotient" and "Cortical Quotient." Scored on 100-point scale for both quotients. Modalities assessed: Spontaneous speech, repetition, comprehension, naming, reading, writing, construction, and Raven's Colored Progressive Matrices. | Validity: Standardized in 365 aphasic and 162 normal individuals. Correlations tested between 1977 and 1982 versions. [d,*] Reliability [d,*] Sensitivity: Not tested. | Uses: Formal assessment, monitoring. Time: 1-4 hours. | Strengths: Widely used, comprehensive. Weaknesses: Administration time long. "Aphasia quotient" and "taxonomy" of aphasia not well validated.

[a] Goodglass and Kaplan, 1972.

[b] Goodglass and Kaplan, 1983.

[c] Porch, 1981.

[d] Kertesz, 1982.

e: adequately evaluated.

Attachment 10. Depression scales

Instrument | Description | Validity, reliability, and sensitivity | Uses and time to administer | Strengths and Weaknesses
Beck Depression Inventory (BDI)[a,b] | Self-rating scale. 21 items (or 13 items in short form) with attitudinal, somatic, and behavioral components. | Validity: Concurrent validity versus the MMPI, Zung, Hamilton Rating Scale, and psychiatric ratings.[**] Reliability[a,c,d,*] Sensitivity[c,d,*] | Uses: Screening and monitoring. Time: 10 minutes. | Strengths: Widely used. Easily administered. Norms available. Good with somatic symptoms. Weaknesses: Less useful in elderly. Somatic items may not be due to depression. Aphasic patients have difficulty. Neglect patients cannot read items. High false positive rates. Face validity makes dissimulation easy.[e]
Center for Epidemiologic Studies Depression (CES-D)[f] | Self-rating scale that measures severity of depressive symptomatology. 20-item questionnaire investigating perceived mood and level of functioning within the past week. | Validity[f,g,h,*] Reliability[g,h,i,*] Sensitivity[g,*] | Uses: Screening and monitoring. Time: < 15 minutes. Useful in elderly. Effective for screening in stroke population. | Strengths: Brief self-report, easily administered. Weaknesses: Not appropriate for aphasic patients
Geriatric Depression Scale (GDS)[j] | Self-rating scale with 30 items in yes/no format. No items refer to disability. | Validity: Concurrent versus Zung and Beck scales and Hamilton scale.[k,l,*] Reliability[k,*] Sensitivity[m,*] | Uses: Screening and monitoring. Time: 10 minutes. | Strengths: Brief. Less affected by visual impairments physical illness, difficulty in choosing options, and poor motivation. Yes/no format better for elderly and cognitively impaired. Weaknesses: High false negative rates in minor depression.
Hamilton Depression Scale[n,o] | 17-item observer-rated scale of somatic and nonsomatic symptoms. | Validity: Concurrent validity versus the present State Exam and Zung Depression Scale.[p,q,r,s,**] Reliability[r,s,t,u][*] | Uses: Screening and monitoring. Time: < 30 minutes. | Strengths: Observer rated rather than self-report; frequently used in stroke patients; combined with Beck increases congruence with DSM-III-R criteria. Weaknesses: Multiple versions with different numbers of items and phrasing of questions compromise interobserver reliability.

[a] Beck, Ward, Mendelson, et al., 1961.

[b] Beck and Steer, 1987.

[c] Schubert, Burns, Paras, et al., 1992a.

[d] Schubert, Burns, Paras, et al., 1992b.

[e] House, Dennis, Hawton, et al., 1989.

[f] Radloff, 1977.

[g] Shinar, Gross, Price, et al., 1986.

[h] Weissman, Sholomskas, Pottengel, et al., 1977.

[i] Parikh, Eden, Price, et al., 1988.

[j] Yesavage, Brink, Rose, et al., 1982-83.

[k] Norris, Gallager, Wilson, et al., 1987.

[l] Robinson and Price, 1982.

[m] Lichtenberg, Christensen, and Metler, 1993.

[n] Hamilton, 1960.

[o] Hamilton, 1967.

[p] Robinson, Parikh, Lipsey, et al., 1993.

[q] Robinson, Starr, Kubos, et al., 1983.

[r] Robinson, Starr, Lipsey, et al., 1985.

[s] Gordon, Hibbard, Egelko, et al., 1991.

[t] Williams, 1988.

[u] Robinson, Starr, Kubos, et al., 1983.

NOTE: * = adequately evaluated. ** = comprehensively evaluated. An additional well-validated instrument is the Zung Scale (Zung, 1965).

Attachment 11. Measures of instrumental activities of daily living (IADL)

Instrument | Description | Validity, reliability, and sensitivity | Uses and time to administer | Strengths and Weaknesses
PGC Instrumental Activities of Daily Living[a] | Guttman scale with questions on use of telephone, walking, shopping, food preparation, housekeeping, laundry, public transportation, and medicine. | Validity[b,*] Reliability[a,c,d,*] | Uses: Maintenance. Time: < 30 minutes. | Strengths: Measures broad base of information necessary for independent living. Weaknesses: Has not been used in stroke population.
Frenchay Activities Index[e] | 15 items concerning activities in and outside the home. Summary score (range 15-60 points) and subscale scores for domestic, leisure/work, and outdoor activities. Depends on patient and family self-reports | Validity: Good correlation with Barthel Index and Sickness Impact Profile scores.[f,*] | Uses: Maintenance. Time: 10-15 minutes. | Strengths: Developed specifically for stroke patients. Assesses broad array of activities of daily living. Weaknesses: Sensitivity not tested but probably limited. Interobserver reliability not tested.

[a] Lawton, 1972.

[b] Rubenstein, Schairer, Wieland, et al., 1984.

[c] Lawton, 1988a.

[d] Lawton, 1988b.

[e] Holbrook and Skilbeck, 1983.

[f] Schuling, de Haan, Limburg, et al., 1993.

NOTE: * = adequately evaluated. Additional useful instruments include OARS: Instrumental ADL (Duke University, 1978), and the Functional Health Status (Rosow and Breslau, 1966).

Attachment 12. Family assessment

Instrument | Description | Validity, reliability, and sensitivity | Uses and time to administer | Strengths and Weaknesses
Family Assessment Device (FAD)[a] | 7 domain scales assessing problem solving, communication, roles, affective responsiveness, affective involvement, behavior control, and general functioning. | Validity[b,c,d,e,f,*] Reliability[a,c,e,g,*] Sensitivity: Not tested. | Uses: Formal assessment, monitoring, and maintenance. Time: < 30 minutes. | Strengths: Widely used in stroke. Computer scoring available. Excellent validity and reliability. Cut-off scores for family functioning. Available in multiple languages. Weaknesses: Assessment subjective. Sensitivity not tested.

[a] Epstein, Baldwin, and Bishop, 1993.

[b] Wenniger, Hagemand, and Arrindell, 1993.

[c] Byles, Bryne, Boyle, et all., 1988.

[d] Fristad, 1989.

[e] Miller, Bishop, Epstein, et al., 1985.

[f] Kabacoff, Miller, Bishop, et al., 1990.

[g] Kaufman, Tarnowski, Simonian, et al., 1991.

Note: * = adequately evaluated.

Attachment 13. Quality-of-life measures

Instrument | Description | Validity, reliability, and sensitivity | Uses and time to administer | Strengths and Weaknesses
Medical Outcomes Study (MOS) 36- Item Short-Form Health Survey.[a] | 36 items with 118 levels. Domains: Physical functioning, role limitations due to physical or emotional problems, social functioning, bodily pain, mental health, vitality, and general health perceptions | Validity: Well demonstrated for a derived 20-item scale. [a,**] Reliability: Well demonstrated for a derived 20-item scale. [a,**] Sensitivity: As sensitive as the Sickness Impact Profile. [b,*] | Uses: Maintenance. Time: 10-15 minutes. | Strengths: Improved version of SF-20. Eight scales are scored separately. All items are well standardized. Brief and can be self-completed or completed by telephone or personal interview. Widely used in the United States. Weaknesses: Possible "floor" effect in seriously ill patients, especially for physical functioning, suggests it should be supplemented by an ADL scale. Further validation studies in progress. Not tested in post-stroke rehabilitation patients.
Sickness Impact Profile (SIP)[c] | 136 items with scores on subscales and summated. 12 subscales: Ambulation, mobility, body care, emotion, communication, alertness, sleep, eating, home management, recreation, social interactions, and employment. | Validity and reliability: Well demonstrated. [c,**] Sensitivity: Ability to detect change questioned. [d,*] | Uses: Maintenance. Time: 20-30 minutes. | Strengths: Comprehensive and well evaluated. Broad range of items reduces "floor" or "ceiling" effects. Weaknesses: Relatively long. Evaluates behavior rather than subjective health. Questions on well-being, happiness, and satisfaction should be added.

[a] Ware and Sherbourne, 1992.

[b] McHorney, Ware, Rogers, et al., 1992.

[c] Bergner, Bobbitt, Carter, et al., 1981.

[d] MacKenzie, Charlson, Digioia, et al., 1986.

Note: * = adequately evaluated. ** = comprehensively evaluated.