# Contributors

## Post-Stroke Rehabilitation Guideline Panel

- Glen E. Gresham, MD
- Chair
- Professor and Chairman
- Department of Rehabilitation Medicine
- State University of New York at Buffalo
- Director of Rehabilitation Medicine
- Erie County Medical Center
- Buffalo, NY

Dr. Gresham is Professor and Chairman of Rehabilitation Medicine at the State University of New York at Buffalo. He was educated at Harvard College and Columbia University and received his clinical training in internal medicine at the University Hospitals of Cleveland. He has served on the faculties of Ohio State University, Yale University, Tufts University, and the State University at Buffalo.

Dr. Gresham became interested in stroke outcomes research in 1970. He published the first description of long-term disability outcomes in the Framingham Stroke Study, plus other analyses of stroke outcome. He continues as a consultant to the Framingham Stroke Study and has written extensive review articles, editorials, and chapters on stroke outcomes research. He is a member of the editorial board of Stroke: A Journal of Cerebral Circulation. In 1984, he and Carl V. Granger, MD, co-edited Functional Assessment in Rehabilitation Medicine, one of the first books in this field. In 1989, he organized an international symposium, "Methodologic Issues in Stroke Outcome Research," which was published as a supplement to Stroke: A Journal of Cerebral Circulation.

Dr. Gresham is a member of the Stroke Council of the American Heart Association and the American Congress of Rehabilitation Medicine. In 1992, he participated on the faculty of the Second World Congress of the International Stroke Society. He is the author of the chapter on stroke rehabilitation in both the first and second editions of Stroke: Pathophysiology, Diagnosis, and Management, edited by H.J.M. Barnett, J.P. Mohr, B.M. Stein, and F.M. Yatsu.

- Pamela W. Duncan, PhD, PT
- Co-Chair
- Associate Professor
- Health Services Administration
- University of Kansas
- Director of Research
- Center on Aging
- Kansas University Medical Center
- Kansas City, KS

Dr. Duncan received her BS in physical therapy from Columbia University and her PhD in epidemiology from the University of North Carolina at Chapel Hill. During the preparation of this guideline, Dr. Duncan was an associate professor of physical therapy in the graduate program at Duke University. Also at Duke, she served as a research associate professor in the Center for Health Policy Research and Education, as well as a senior fellow in the Center for Aging and Human Development. From 1991 to 1994, she served as project director for the Stroke PORT, a 5-year study of secondary and tertiary prevention of stroke, funded by the Agency for Health Care Policy and Research. She is coinvestigator in Duke University's Claude Pepper Older American Independence Center Research.

Dr. Duncan is co-author of a book on stroke, Stroke Rehabilitation: Recovery of Motor Control. She has authored several papers on measurement and recovery of motor function following stroke. She has contributed to many publications on the measurement of physical performance in the frail elderly, and assessment of falls and imbalance in the elderly. Dr. Duncan has served the American Physical Therapy Association in many capacities and is immediate past president of the neurology section. She is a fellow of the Stroke Council of the American Heart Association and a member of the board of directors of the National Stroke Association.

In August 1994, she joined the faculty of the University of Kansas to develop a research program in geriatric rehabilitation outcomes and physical disability.

- Harold P. Adams, Jr., MD
- Professor of Neurology and Director
- Division of Cerebrovascular Diseases
- University of Iowa College of Medicine
- Iowa City, IA

Dr. Adams is Professor and Director of the Division of Cerebrovascular Diseases, Department of Neurology, University of Iowa College of Medicine. His undergraduate education was at Drake University and the University of South Dakota. He received his MD degree from Northwestern University and performed his residency in neurology at the University of Iowa. He is certified in neurology by the American Board of Psychiatry and Neurology. Dr. Adams is a fellow of the American Academy of Neurology, American College of Physicians, and Stroke Council of the American Heart Association. He is also a member of the American Neurological Association. He serves on the editorial or advisory boards of Stroke, Cerebrovascular Diseases, and Journal of Stroke and Cerebrovascular Disease.

Dr. Adams has authored approximately 190 papers and chapters, largely dealing with stroke. He edited the Handbook of Cerebrovascular Diseases, which appeared in 1993. He has participated in a number of clinical studies and trials in stroke and is principal investigator of a NINDS-funded randomized trial that is testing the usefulness of heparinoid, Org 10172, in improving outcome after stroke. The Stroke Council of the American Heart Association named Dr. Adams as recipient of the 1993 Humana Award for excellence in clinical stroke research.

- Alan M. Adelman, MD, MS
- Associate Professor and Director of Research
- Department of Family and Community Medicine
- Pennsylvania State University
- The Milton S. Hershey Medical Center
- Hershey, PA

Dr. Adelman is Associate Professor and Director of Research in the Department of Family and Community Medicine, Pennsylvania State University. He received his MD degree in 1975 from Temple University School of Medicine, Philadelphia, Pennsylvania. He performed his residency training in family medicine at Kaiser Foundation Hospital in Los Angeles, California. Upon completing his residency training, he served 3 years in the U.S. Public Health Service at the Keams Canyon Indian Health Service Hospital, Keams Canyon, Arizona.

He completed a Robert Woods Johnson Family Practice Faculty Development Fellowship at the University of Iowa in 1983. At that time, he also received a master's degree in preventive medicine. He has served on the faculties of the Department of Family Medicine at the University of Connecticut and University of Maryland, prior to his current position at the Hershey Medical Center. He has extensive experience and added qualifications in geriatrics. Prior to his present appointment, Dr. Adelman served as the medical director of the geriatric rehabilitation unit at the James Lawrence Kernan Hospital, Baltimore, Maryland (an affiliate of the University of Maryland Medical System).

- David N. Alexander, MD
- Director of Stroke Rehabilitation
- Center for Diagnostic and Rehabilitation Medicine
- Daniel Freeman Hospital
- Assistant Clinical Professor
- Department of Neurology
- University of California at Los Angeles School of Medicine
- Los Angeles, CA

Dr. Alexander is a neurologist whose primary clinical focus for the past 10 years has been on neurological rehabilitation. Currently, he is the Director of Stroke Rehabilitation at the Center for Diagnostic and Rehabilitation Medicine at Daniel Freeman Hospital, and Associate Clinical Professor at the UCLA School of Medicine, Department of Neurology. An honors graduate both of Amherst College and the University of Minnesota Medical School, Dr. Alexander was an intern in medicine at University Hospital in Boston and a resident in neurology at the Neurological Institute of New York at Columbia-Presbyterian Medical Center. He is actively engaged in clinical research, scholarly publication, and teaching of neurorehabilitation. He is a fellow of the Stroke Council of the American Heart Association, a site surveyor for the Commission on Accreditation of Rehabilitation Facilities, and a member of the American Society of Neurorehabilitation.

- Duane S. Bishop, MD
- Director, Rehabilitation Psychiatry
- Rhode Island Hospital
- Associate Professor
- Department of Psychiatry
- Brown University
- Providence, RI

Dr. Bishop received his MD at the University of Alberta, Canada, and completed his residency in psychiatry at the McMaster University, Canada. Dr. Bishop is Associate Professor of Psychiatry, Department of Psychiatry and Human Behavior, Brown University, Providence, Rhode Island, and also the Director of Rehabilitation Psychiatry at Rhode Island Hospital in Providence. Along with Dr. Nathan Epstein, he was an originator of the McMaster Model of Family Functioning and the Problem Centered Systems Therapy of the Family Model, the McMaster Family Assessment Device (FAD), and the McMaster Clinical Rating Scale (CRS). He led the group's development of the McMaster Structured Interview of Family Functioning (McSIFF). Dr. Bishop has completed numerous research studies on the families of psychiatric and chronic illness (including stroke) populations. Dr. Bishop has published more than 90 articles and abstracts, has been a visiting professor at several international universities, and has made many national and international presentations.

- Leonard Diller, PhD
- Chief and Professor
- Behavioral Science and Clinical Rehabilitation Medicine
- Rusk Institute of Rehabilitation Medicine
- New York University Medical Center
- New York, NY

Dr. Diller received his PhD in clinical psychology from New York University in 1953. Since 1952, he has been associated with the Rusk Institute of Rehabilitation Medicine at NYU Medical Center. He is currently Chief of Psychological Services and Director of Behavioral Sciences. Dr. Diller has been a professor of clinical rehabilitation medicine since 1972.

His research has been in the development of approaches to improve cognitive deficits in individuals with brain damage. He has directed a number of federally funded research programs and is currently the director of a research and training center in head trauma and stroke, sponsored by the National Institute on Disability and Rehabilitation Research. He has authored more than 100 articles in the professional literature.

Dr. Diller has served as president of the American Congress of Rehabilitation Medicine and president of the Rehabilitation Psychological Association, and has been program committee chairman of the International Neuropsychological Society. He has been a grant reviewer for the major Federal research agencies; and he has been on the editorial boards of nine major journals in the field.

Dr. Diller was the first recipient of the Hayden Williams Fellowship of the Western Australian Institute of Technology in studies in psychology and the Caveness Memorial Award of the National Head Injury Foundation. He has received meritorious service awards from the New York State United Cerebral Palsy Association and the New York Chapter of the National Rehabilitation Association. In 1992, he was a recipient of the Gold Key Award from the American Congress of Rehabilitation Medicine.

- Nancy E. Donaldson, RN, DNSc
- Consumer Representative
- Newport Beach, CA

Dr. Donaldson received her nursing degree and master's of nursing science from California State University at Los Angeles and her doctorate from the University of California at San Francisco. Dr. Donaldson (Mrs. Stephen E. Donaldson) has a longstanding interest in family adaptation during transitions in health. Following her husband's stroke in 1989, she experienced firsthand the demands and challenges of family adaptation and caregiving. Formerly, she served as the principal investigator, Orange County Research Utilization in Nursing Project. Dr. Donaldson is the Executive Director, Clinical Effectiveness, Quality Outcomes Management Services, UniHealth America, Burbank, California.

- Carl V. Granger, MD
- Professor of Rehabilitation Medicine and Director
- Center for Functional Assessment Research
- State University of New York at Buffalo
- Buffalo, NY

Dr. Granger received his MD from New York University. Since 1983, he has been Professor of Rehabilitation Medicine at the State University of New York at Buffalo. He was also the former head of the Department of Rehabilitation Medicine at Buffalo General Hospital. He is Associate Chairman of Rehabilitation Medicine, Director of the Center for Functional Assessment Research, Department of Rehabilitation Medicine, and Co-Director of the University at Buffalo Multiple Sclerosis Center.

Dr. Granger has completed more than 80 publications, including "Outcome of Comprehensive Medical Rehabilitation: Measurement by PULSES Profile and the Barthel Index," in collaboration with G.L. Albrecht and B.B. Hamilton. This journal article appeared in Archives of Physical Medicine and Rehabilitation (1979). He has been awarded the Elizabeth and Sidney Licht Award for Excellence in Scientific Writing. He is also co-editor with G.E. Gresham of Functional Assessment in Rehabilitation Medicine (Williams & Wilkins, 1984), and co-author with G.B. Seltzer and C. Fishbein of Primary Care of the Functionally Disabled (Lippincott, 1987).

- Audrey L. Holland, PhD
- Professor and Head
- Department of Speech and Hearing Sciences
- University of Arizona
- Tucson, AZ

Audrey L. Holland received her PhD from the University of Pittsburgh. Currently, she is Professor and Head, Department of Speech and Hearing Sciences, University of Arizona. The major focus of her research, clinical service, and teaching has been on neurogenic communication disorders, with a primary emphasis on clinically relevant research in aphasia. She has served on the advisory board of the National Institute of Deafness and Other Communication Disorders, as well as on the editorial boards of a number of professional journals, and recently completed a term as chair of the board of governors of the Academy of Aphasia. She has published more than 100 articles related to neurogenic communication disorders, and frequently lectures on clinical management of aphasia and related problems. In 1990, she received the honors of the association from the American-Speech-Language-Hearing Association.

- Margaret Kelly-Hayes, EdD, RN, CRRN
- Research Coordinator and Investigator
- Neuroepidemiology Section, Department of Neurology
- Boston University School of Medicine
- Boston, MA

Dr. Kelly-Hayes is Associate Clinical Professor of Neurology (neurological nursing) at Boston University School of Medicine and Neurology Projects Director, the Framingham Stroke Study. Her degrees include a BS in nursing from Boston College, a master's in rehabilitation nursing, and a doctorate in health education from Boston University. Dr. Kelly-Hayes' research activities focus on the neuroepidemiology of stroke. She has authored numerous articles on rehabilitation nursing, stroke prevention, and post-stroke recovery. In 1991, she was co-editor for Nursing Clinics of North America on stroke. Dr. Kelly-Hayes has represented rehabilitation nursing on several national committees, including the national advisory board for the Uniform Data System for Medical Rehabilitation. She is also an elected fellow to the American Heart Association's Council on Stroke.

- Fletcher H. McDowell, MD
- Executive Medical Director
- Burke Rehabilitation Hospital
- White Plains, NY
- Associate Dean and Winifred Masterson Burke Professor of Neurology and Rehabilitation Medicine
- Cornell University Medical College
- New York, NY

Dr. McDowell is the Winifred Masterson Burke Professor of Rehabilitation Medicine at Cornell University Medical College and is Professor of Neurology at Cornell University Medical College. He is currently the Executive Medical Director of the Burke Rehabilitation Hospital, White Plains, New York. He is also the Associate Dean of Cornell University Medical College.

Dr. McDowell is a graduate of Dartmouth College and received his MD from Cornell University Medical College in New York City. He has served as chairman of the board of directors of the National Stroke Association and is currently the president of the organization. Dr. McDowell has published extensively on clinical neurology, stroke, Parkinson's disease, and rehabilitation medicine. He is past editor of the American Heart Association's journal Stroke and is currently an associate editor of the journal of Stroke and Cerebral Vascular Disease. He is a member of the American Neurological Association and the American Academy of Neurology.

- Larry R. Myers, MD
- Clinician, Office-Based Practice
- Ambulatory Sentinel Practice Network
- Community Preceptor
- Mansfield, TX

Dr. Myers is a residency-trained family physician, practicing rural and semirural primary care for 15 years. Initially trained as a fighter pilot in Vietnam (following graduation from the Naval Academy at Annapolis), he received his medical education at the University of Arizona. Following residency training at the Medical University of South Carolina, he began practicing rural medicine as part of the Robert Wood Johnson Foundation's Rural Practice Project in northern Michigan. Subsequently, he has joined his practice in Texas, as a research clinician with the Ambulatory Sentinel Practice Network, an affiliation of primary care practices across the United States and Canada. (Dr. Myers also practices rural emergency medicine.)

He is a member of the American Academy of Family Physicians, Society of Teachers of Family Medicine, and NAPCRG. His primary interests are rural primary care, illness behavior, and geriatrics.

- Marion A. Phipps, RN, MS, CRRN, FAAN
- Rehabilitation Nurse Specialist
- Beth Israel Hospital
- Boston, MA

Marion Phipps is a rehabilitation nurse specialist at the Beth Israel Hospital in Boston, Massachusetts. Ms. Phipps received her nursing degree from the University of New Hampshire and a master's in rehabilitation nursing from Boston University. Her areas of interest include the application of rehabilitation nursing approaches in the acute care setting, care of stroke patients, and geriatric rehabilitation. Ms. Phipps is a fellow of the American Academy of Nursing and a member of Sigma Theta Tau. She is certified in rehabilitation nursing and is an active member of the Association of Rehabilitation Nurses (having served on local and national committees). Ms. Phipps has written numerous rehabilitation nursing articles, and she served as a guest editor for the 1991 Stroke Symposium in Nursing Clinics of North America.

- Elliot J. Roth, MD
- Director
- Rehabilitation Institute of Chicago
- Professor
- Department of Physical Medicine and Rehabilitation
- Northwestern University Medical School
- Chicago, IL

Dr. Roth received his AB in chemistry and human services education from the Washington University, St. Louis. He received his MD from the Northwestern University Medical School. Dr. Roth interned at Cook County Hospital in Chicago, and he completed his residency and fellowship at the Northwestern University Medical School/Rehabilitation Institute of Chicago.

Dr. Roth is Director of the Rehabilitation Institute of Chicago and Professor of Physical Medicine and Rehabilitation at Northwestern University Medical School. He has also served as associate director of spinal cord injury rehabilitation for the Midwest Regional Spinal Cord Injury Care System.

He has published numerous peer-reviewed papers, reviews, and chapters on a variety of topics related to stroke and rehabilitation, and he has directed several research grants. Dr. Roth gives more than 50 lectures a year and recently received an outstanding teaching award. He serves on the editorial boards of several journals and is chairman of the rehabilitation committee of the American Heart Association of Metropolitan Chicago. Dr. Roth's clinical and academic interests are in the areas of comorbidity, outcome assessment, and rehabilitation management of stroke patients.

- Hilary C. Siebens, MD
- Medical Director
- Skilled Nursing and Assessment Center
- Medical Director
- Rehabilitation Research
- Cedars Sinai Medical Center
- Assistant Clinical Professor
- Department of Medicine,
- Division of Physical Medicine and Rehabilitation
- University of California at Los Angeles
- Los Angeles, CA

Dr. Siebens received her MD from Harvard Medical School, her board certification in internal medicine after training at Johns Hopkins Hospital, her special qualifications in geriatric medicine after a geriatric fellowship at Harvard University, and her board certification in physical medicine and rehabilitation after a residency at Tufts University.

She currently is Assistant Medical Director, Department of Physical Medicine and Rehabilitation, Cedar-Sinai Medical Center, Los Angeles, California. At UCLA, she is an assistant clinical professor in the Department of Medicine/Geriatric Medicine, Division of Physical Medicine and Rehabilitation. Her clinical work over the past 6 years has included treatment of 450 stroke inpatients, 1,200 rehabilitation outpatient visits, 1,300 acute hospital consultations, and medical directorship of the Cedar-Sinai Medical Center's 30-bed hospital-based skilled nursing facility.

Dr. Siebens has received research support from the Eleanor Naylor Dana Charitable Trust for a study on blood volumes after hip fracture, from NIH for a pilot study on stroke outcomes, and from the John A. Hartford Foundation for a randomized controlled trial of exercise in older hospitalized patients. She has consulted on a multicenter HCFA study at the University of Colorado on stroke and hip fracture rehabilitation outcomes. She has also consulted on a Robert Wood Johnson-funded study on innovative rehabilitation care outcomes in stroke, hip fracture, and medical/surgical patients.

She has published original research on eating disabilities, normal blood volumes in older adults, and blood volumes after vascular surgery and hip fracture; and review chapters on the topics of geriatric rehabilitation, medications in older rehabilitation patients, and deconditioning in older adults.

- Gloria A. Tarvin, MSW, LSW
- Chairperson of Allied Health/Nursing and Director of Social Work
- Rehabilitation Institute of Chicago
- Chicago, IL

Gloria Tarvin is Chairperson of Allied Health/Nursing and Director of Social Work, Rehabilitation Institute of Chicago. She is an instructor of clinical rehabilitation in the Department of Physical Medicine and Rehabilitation at Northwestern University Medical School. She earned her AB degree from Brown University and her MSW degree from Atlanta University School of Social Work.

Ms. Tarvin is currently on the board of directors of the Society of Social Work Administrators in Health Care of the American Hospital Association. She is on the consulting editor's board of Health and Social Work. Her teaching experience includes topics related to rehabilitation and social work, both clinical and administrative.

- Catherine A. Trombly, ScD, OTR/L, FAOTA
- Professor of Occupational Therapy
- Sargent College of Allied Health Professions
- Boston University
- Boston, MA

Catherine Trombly is a certified and licensed occupational therapist and fellow of the American Occupational Therapy Association. She received her basic professional training in occupational therapy at the University of New Hampshire and completed graduate study in occupational therapy at the University of Southern California (MA) and at Boston University (ScD). Her area of specialization is adult physical dysfunction. Her clinical experience, obtained at Highland View Hospital in Cleveland, includes rehabilitation of patients with neurological disorders, especially stroke and spinal cord injury. Currently, she is Professor of Occupational Therapy, Sargent College of Allied Health Professions, Boston University.

Dr. Trombly is a charter member of the American Occupational Therapy Foundation's Academy of Research. Her primary post-stroke research interest is the study of the mechanisms of motor impairment, and the effectiveness of therapy to remediate those impairments.

Catherine Trombly is the editor and major author of Occupational Therapy for Physical Dysfunction, published by Williams & Wilkins. It was the first textbook for therapists and students interested in the treatment of physical disabilities. The fourth edition is now in progress.

## Other Contributors [1] [1] Being listed in this section does not necessarily imply endorsement of the guideline products.

### Consultants

- Robert F. Berrian, MA, CTRS
- Director of Recreational Therapy Services
- Health South Rehabilitation Center
- Mechanicsburg, PA
- Specialty: Therapeutic Recreation

- Richard W. Bohannon, EdD, PT, NCS
- Professor
- School of Allied Health
- University of Connecticut
- Storrs, CT
- Therapist
- Hartford Hospital
- Hartford, CT
- Specialty: Physical Therapy

- James S. Liljestrand, MD, MPH
- Medical Director
- Braintree Hospital
- President
- National Association of Rehabilitation Facilities
- Braintree, MA
- Specialty: Internal Medicine

- Fay W. Whitney, RN, PhD, FAAN
- Assistant Professor
- School of Nursing
- University of Pennsylvania
- Philadelphia, PA
- Specialty: Rehabilitation Nursing

### Peer Reviewers, Guideline Technical Report

- Michael Alexander, MD
- Director, Stroke Rehabilitation
- Braintree Hospital
- Braintree, MA
- Associate Professor of Neurology
- Boston University
- Boston, MA
- Stephen N. Berk, PhD
- Director
- Department of Psychology
- Moss Rehabilitation Hospital
- Philadelphia, PA

- Murray E. Brandstater, MBBS, PhD
- Professor and Chairman
- Department of Physical Medicine and Rehabilitation
- School of Medicine
- Loma Linda University
- Loma Linda, CA

- Kathryn S. Bronstein, PhD, RN
- Clinical Nurse Specialist
- Cerebrovascular Neurosurgery
- Northwestern Medical Facility/Foundation
- Chicago, IL

- Bruce M. Caplan, PhD
- Chief Psychologist and Associate Professor
- Thomas Jefferson University Hospital
- Department of Rehabilitation Medicine
- Philadelphia, PA

- Catherine A. Clancy, PhD, CSW-ACP
- Director
- Social Service Department
- St. Luke's Episcopal Hospital
- Houston, TX

- Catherine Coyle, CTRS, PhD
- Associate Professor
- Temple University
- Philadelphia, PA

- Mary Dombovy, MD
- Assistant Professor of Neurology and Rehabilitation
- University of Rochester
- New York
- Chair
- Department of Physical Medicine and Rehabilitation
- St. Mary's Hospital
- Rochester, NY

- Nancy Doolittle, PhD, RN
- Research Nurse
- Department of Physiological Nursing
- University of California, San Francisco
- San Francisco, CA

- Ron L. Evans, ACSW
- Clinical Assistant Professor
- University of Washington School of Medicine
- Department of Rehabilitation Medicine
- Seattle, WA

- Mary M. Evert, MBA, OTR, FAOTA
- President
- American Occupational Therapy Association
- McLean, VA

- Carol Frattali, PhD
- Director
- Health Services Division
- American Speech-Language-Hearing Association
- Rockville, MD

- Marcus J. Fuhrer, PhD
- Director
- National Center for Medical Rehabilitation Research
- National Institute of Child Health and Human Development
- Rockville, MD

- Kenda Fuller, PT, NCS
- Lutheran Hospital
- Wheat Ridge, CO

- Gary Goldberg, MD
- Associate Professor
- Department of Physical Medicine and Rehabilitation
- Temple University School of Medicine
- Consultant
- Stroke Center
- Moss Rehabilitation Hospital
- Philadelphia, PA

- Wayne A. Gordon, PhD
- Professor and Associate Director
- Mt. Sinai School of Medicine
- New York, NY

- Mark V. Johnston, PhD
- Director of Outcome Research
- Kessler Institute for Rehabilitation
- University of Medicine and Dentistry of New Jersey
- New Jersey Medical School
- West Orange, NJ

- Lyn Jongbloed, OTR, PhD
- Associate Professor
- School of Rehabilitation Sciences
- University of British Columbia
- Vancouver, BC, Canada

- Richard B. Lazar, MD
- Executive Vice President, Medical Director
- Schwab Rehabilitation Hospital
- Departments of Neurology and Physical Medicine and Rehabilitation
- Northwestern University Medical School
- Chicago, IL

- Jeri A. Logemann, PhD
- Professor and Chairman
- Department of Communication Sciences and Disorders
- Northwestern University
- Evanston, IL

- James Malec, PhD, LP, ABPP
- Neuropsychologist
- Mayo Medical Center
- Rochester, MN

- Richard S. Materson, MD
- National Rehabilitation Hospital
- Washington, DC

- John Melvin, MD
- Vice President of Medical Affairs
- Moss Rehabilitation Hospital
- Chairman
- Physical Medicine and Rehabilitation
- Albert Einstein Medical Center
- Professor and Deputy Chairman
- Department of Physical Medicine and Rehabilitation
- Temple University
- Philadelphia, PA

- Christina M. Mumma, PhD, RN, CRRN
- Associate Professor and Chair
- Graduate Nursing Program
- University of Alaska
- Anchorage, AK

- Kenneth Ottenbacher, PhD, OTR
- Professor and Associate Dean
- School of Health-Related Professions
- State University of New York at Buffalo
- East Amherst, NY

- Walter Panis, MD
- Assistant Director of Neurology
- Spaulding Rehabilitation Hospital
- Boston, MA

- Frances Pendergraft
- Executive Director of Counseling Services
- Institute for Rehabilitation and Research
- Houston, TX

- Judith M. Popovich, DNSc, RN, CRRN
- Assistant Professor
- College of Nursing
- University of Kentucky
- Lexington, KY

- Thomas R. Price, MD
- Professor of Neurology, Epidemiology, and Preventive Medicine
- University of Maryland Hospital
- Baltimore, MD

- Michael J. Reding, MD
- Associate Professor of Neurology
- Cornell University Medical College at Burke Rehabilitation Hospital
- White Plains, NY

- J. Scott Richards, PhD
- Director of Psychology
- Spain Rehabilitation Center
- Birmingham, AL

- Jay H. Rosenberg, MD
- Chairman, Quality Standards Subcommittee
- American Academy of Neurology
- Clinical Associate Professor of Neurology
- University of California at San Diego School of Medicine
- Staff Neurologist
- Southern California Permanente Medical Group
- San Diego, CA

- Shirley A. Sahrmann, PhD, PT
- Associate Professor, Physical Therapy and Neurology
- Washington University School of Medicine
- St. Louis, MO

- Margaret Stinemen, MD
- Assistant Professor of Rehabilitation Medicine
- University of Pennsylvania
- Philadelphia, PA

- J. Paul Thomas, PhD
- Director, Medical Sciences Programs
- National Institute on Disability and Rehabilitation Research
- U.S. Department of Education
- Washington, DC

- James F. Toole, MD
- Director, Stroke Research Center
- Bowman Gray School of Medicine
- Winston-Salem, NC

- Karin Mueck Vecchione, MEd, CTRS
- Administrator
- Senior Network, Inc.
- Oxon Hill, MD

- Derick T. Wade, MD
- Consultant in Neurological Disability
- Rivermead Rehabilitation Centre
- Oxford, United Kingdom

- Robert T. Wertz, PhD
- Professor
- Hearing and Speech Sciences
- Vanderbilt University School of Medicine
- VA Medical Center
- Nashville, TN

- Jack Whisnant, MD
- Chair
- Department of Health Services Research
- Professor of Neurology
- Mayo Medical School
- Rochester, MN

- Anne M. Woodson, OTR
- University of Texas Medical Branch at Galveston
- Galveston, TX

- Kathryn M. Yorkston, PhD
- Professor of Rehabilitation Medicine
- University of Washington
- Seattle, WA

- Mark A. Young, MD
- Department of Rehabilitation Medicine
- Johns Hopkins University School of Medicine
- Baltimore, MD

- Richard Zorowitz, MD
- Assistant Professor
- Department of Physical Medicine and Rehabilitation
- University of Medicine and Dentistry/New Jersey Medical School
- Newark, NJ
- Clinical Chief
- Stroke Services
- Kessler Institute for Rehabilitation
- West Orange, NJ

### Peer Reviewers: Clinical Practice Guideline, Quick Reference Guide for Clinicians, and the Patient and Family Guide

- Vivian Beyda, DrPH
- Director
- Barrier Free Design and Communication
- New York, NY
- Eastern Paralyzed Veterans Association

- Joseph Bleiberg, PhD
- Director of Psychology
- National Rehabilitation Hospital
- Washington, DC
- American Psychological Association

- Laura Todd Brown, PA-C
- American Academy of Physician Assistants
- Aledo, TX
- American Academy of Physician Assistants

- Louis R. Caplan, MD
- Department of Neurology
- New England Medical Center
- Boston, MA
- American Academy of Neurology

- Pat Carter
- Associate Administrator
- Hebrew Home of Greater Washington
- Rockville, MD
- American Association of Homes for the Aging

- Randall Cebul, MD
- Associate Professor of Medicine and Epidemiology, Biostatistics
- Case Western Reserve University
- MetroHealth Medical Center
- Cleveland, OH
- Society of General Internal Medicine

- Gregg R. Clifford, MD
- Consultants in Internal Medicine, Ltd.
- Norfolk, VA
- American College of Physicians

- Steven Cohen-Cole, MD
- Wesley Woods Geriatric Hospital
- Atlanta, GA
- American Psychiatric Association

- Gregory Jay Darby, PA-C
- Rehabilitation Medicine Association
- Gainesville, FL
- American Academy of Physician Assistants

- Susan Dean-Baar, PhD, RN, CRRN
- Wheeling, IL
- American Nurses Association

- Alicejean L. Dodson, RN, MN
- Washington, DC
- American Health Care Association

- Wayne R. English, DO, FAOCRM
- Sportsmedicine Rehabilitation Center
- Bedford, TX
- American Osteopathic Association

- Bruce M. Gans, MD
- President and CEO
- Rehabilitation Institute of Michigan
- Detroit, MI
- American Hospital Association

- Arthur M. Gershkoff, MD
- Clinical Director
- Moss Rehabilitation Stroke Center
- Philadelphia, PA
- Moss Rehabilitation Hospital

- Mary Jo Gibson
- Senior Analyst
- Public Policy Institute
- Washington, DC
- American Association of Retired Persons

- Gary Goldberg, MD
- Philadelphia, PA
- American Academy of Physical Medicine and Rehabilitation

- Elizabeth Gresch
- President
- Dow Chemical Company
- Midland, MI
- American College of Occupational and Environmental Medicine

- Michael Hagen, MD
- Associate Professor and Interim Chair
- Department of Family Practice
- University of Kentucky
- Lexington, KY
- American Academy of Family Physicians

- Carolyn J. Harris, RN, BSN, MEd, NHA
- Marlin Management Services, Inc.
- Burlington, VT
- American Health Care Association

- Melinda Harrison
- Director
- Watson Clinic Center for Rehabilitative Medicine
- Lakeland, FL
- American Speech-Language-Hearing Association

- Jim Hinojosa, PhD, OTR, FAOTA
- Associate Professor and Director of Post-Professional Graduate Program
- Department of Occupational Therapy
- New York University
- New York, NY
- American Occupational Therapy Association

- Gary R. Houser
- President
- National Stroke Association
- Englewood, CO
- National Stroke Association

- Jeanette Hoyt, CRRN
- Willamette Falls Hospital--Home Health Agency
- Oregon City, OR
- National Association for Home Care

- Katherine F. Jeter, EdD, ET
- Executive Director
- Help for Incontinent People, Inc.
- Spartanburg, SC
- Help for Incontinent People, Inc.

- Philip W. Kassirer, PT
- Director of Therapeutic Services
- HCR--Home Health Agency
- Rochester, NY
- National Association for Home Care

- Kathleen Kelly
- Executive Director
- Family Caregiver Alliance
- San Francisco, CA
- Family Caregiver Alliance

- Evelyn Kennedy
- Executive Director
- Promote Real Independence for the Disabled and Elderly
- Groton, CT
- Promote Real Independence for the Disabled and Elderly

- Corinne Kirchner, PhD
- Director of Social Research
- American Foundation for the Blind
- New York, NY
- American Foundation for the Blind

- Paul Leung, PhD
- Division of Rehabilitation Education Services
- University of Illinois
- Champaign, IL
- American Psychological Association

- Sharon M. Lyke, RN, BSN, CRRN
- Hilltop Home Care
- Grand Junction, CO
- National Association for Home Care

- Marjorie A. Maddox, ARNP, ANP-C
- University of Louisville School of Nursing
- Louisville, KY
- American Academy of Nurse Practitioners

- Jane Mathews-Gentry, PT, MPH, DSc
- Rehabilitation Supervisor
- VNA/North Shore, Inc.
- Danvers, MA
- National Association for Home Care

- John L. Melvin, MD
- Philadelphia, PA
- National Association of Rehabilitation Facilities

- Stephanie Mensh
- Falls Church, VA
- American Urological Association

- John Murphy, MD
- Washington, DC
- Gerontological Society of America

- Jonathan Musher, MD
- Vice President of Medical Affairs
- Beverly Enterprises
- Fort Smith, AR
- American Health Care Association

- Glenn E. Nancarrow, PT
- Santa Fe Home Care
- Gainesville, FL
- National Association for Home Care

- Jane M. O'Toole, ARNP
- Santa Fe Home Care
- Gainesville, FL
- National Association for Home Care

- Alberta Orr, MSW
- National Program Associate American Foundation for the Blind
- New York, NY
- American Foundation for the Blind

- Robin J. Patterson, BSN, RN
- Quality Validation Specialist
- Unicare Health Facilities, Inc.
- Spokane, WA
- American Health Care Association

- Kriste Petite, RN, MSN, COHN
- Intel Corporation
- Santa Clara, CA
- American Association of Occupational Health Nurses

- Marcia B. Richards, RN, RS
- Washington, DC
- American Health Care Association

- Robert Robinson, MD
- Department of Psychiatry
- University of Iowa Hospitals and Clinics
- Iowa City, IA
- American Psychiatric Association

- H. Denman Scott, MD, FACP
- Philadelphia, PA
- American College of Physicians

- Thomas K. Skalko, PhD, CTRS
- Florida International University
- Miami, FL
- American Therapeutic Recreation Association

- Andrew H. Smith
- Research Analyst
- American Association of Retired Persons
- Washington, DC
- American Association of Retired Persons

- Mary T. St. Pierre
- Associate Director of Regulatory Affairs
- National Association for Home Care
- Washington, DC
- National Association for Home Care

- Joan Unger, RN/ARNP-C, MS, CNA
- Land O'Lakes, FL
- American Academy of Nurse Practitioners

- Donna L. Wagner, PhD
- Vice President of Programs
- National Council on the Aging, Inc.
- Washington, DC
- National Council on the Aging, Inc.

- Sandra M. Watchous, MN, RN
- Hays, KS
- National Association for Home Care

- Barb Wegener, RN, BSN, MPA, CNAA
- Program Manager: Specialty Services
- Brevard Home Care
- Wuestoff Health Systems
- Melbourne, FL
- National Association for Home Care

- Leon A. Weisberg, MD
- Tulane University School of Medicine
- Department of Psychiatry and Neurology
- New Orleans, LA
- American Society of Internal Medicine

- Rita Wray, BSN, CNA
- Brandon, MS
- National Black Nurses Association

- Kathleen Wreford, RD
- American Dietetic Association
- Clinical Dietitian
- Rehabilitation Institute of Michigan
- Detroit, MI
- American Dietetic Association

### Site Testers

- Helen S. Philliou, RN, BS
- Case Management Consultant
- Winchester, MA

- LaDonna Reading
- Director of Clinical Services
- Continental Medical Systems
- Mechanicsburg, PA

- Joseph W. Vick Roy, MD
- HEALTHSOUTH
- Rehabilitation Hospital of Utah
- Sandy, UT

- Joanne Buttery, MSc
- Stroke Team Coordinator
- Timothy Meagher, MD
- Christiane Gauthier, PhT
- Physiotherapy
- Lawrence Green, MD
- Lilian Heimbach, OT, BSc
- Occupational Therapy
- Diane Larochelle, BSW
- Louisette LaRochelle, BSW
- Social Work
- Annick Leboeuf-Lorange, BSc
- Nursing
- Judith Robillard Shultz, MSc
- Speech-Language Pathology
- Montreal General Hospital
- Montreal, Quebec, Canada

- John B. Anderson, MD, FRCP
- Department of Neurology Permanente Medical Group, Inc.
- Oakland, CA

- G. Nancy McGowan, RN, BSN, CRRN
- Director of Utilization Management
- Olsten Kimberly Quality Care
- Westbury, NY

- John A. Schuchmann, MD
- Chairman
- Scott and White Clinic
- Temple, TX

- Mary Finn, OTR/L
- Coordinator of Program Evaluation
- Spaulding Rehabilitation Hospital
- Boston, MA

- Catherine Kroll, DO
- Gwinn Medical Center UPRNet
- Gwinn, MI

- Marcie Barnette, RN, MSN, FNP
- Director of Clinical Services
- VNA of Washington, DC

- Keith Rafal, MD
- Regional Medical Director
- Susan Anderson, MS, CCC
- Speech-Language Pathologist
- Mindy Grodofsky-Gilmore, LICSW, BCD
- Nancy A. Lowenstein, MS, OTR
- Jeanne Stack, RN
- Senior Resource Clinician
- Wellmark Health Care Services
- Wellesley, MA

### Organizations and Individuals Providing Additional Scientific, Technical, and Administrative Support

#### Center for Health Economics Research

- William B. Stason, MD, MS
- Project Director

- A. James Lee, PhD
- Project Manager/Economist

- Ann Venable, MA
- Scientific Writer

- Cheryl S. Lewis
- Administrative Assistant

- Carol J. Ammering
- Analyst

- Monika Reti
- Analyst

- Holly A. Cyr
- Analyst

- Joyce Huber, PhD
- Senior Economist

- Helen Margulis, MS
- Programmer

- Robyn Tarantino
- Programmer

- Philip W. Tyo
- Administrative Assistant

- Adam J. Falk
- Analyst

- Amy Rensko
- Analyst

#### Harvard School of Public Health

- Sidney Klawansky, MD, PhD
- Thomas Chalmers, MD
- Meta-Analysis

#### Massachusetts PRO

- Peter Maselli, MD
- Medical Director
- Review Criteria

#### Agency for Health Care Policy and Research

- Douglas B. Kamerow, MD, MPH
- Director
- Office of the Forum for Quality and Effectiveness in Health Care

- David C. Lanier, MD
- Project Officer

- Timothy F. Campbell
- Managing Editor

- Valna Montgomery
- Product Manager