# Glossary

## Rehabilitation Professions

### Medical Specialties

All physicians have completed 3 or 4 years of undergraduate college education and 4 years of medical school, and most have completed residency training in a specialty. During rehabilitation, the physician treats medical problems and often functions as the team leader. Physiatry and neurology are the medical specialties most commonly involved in rehabilitation. Geriatricians, internists, family physicians, and psychiatrists may also be involved.

Neurologist.: Specializes in the diagnosis and treatment of diseases of the nervous system and has completed a minimum of 4 years of residency training after medical school.

Physiatrist.: Specializes in physical medicine and rehabilitation and has completed a minimum of 4 years of residency training in physical medicine and rehabilitation after medical school.

Geriatrician.: Specializes in internal medicine or family practice and has completed a minimum of 3 years of residency training after medical school, with additional training in the care of the elderly.

### Occupational Therapy (OT)

Occupational therapists are primarily concerned with helping the patient learn to perform tasks and activities required by daily life.

Registered occupational therapist (OTR).: Has completed 4 years of college and a 6-month supervised internship, and has been examined and certified by the American Occupational Therapy Certification Board (AOTCB).

Certified occupational therapist assistant (COTA).: Has completed a 2-year or associate degree and a 12-week supervised internship, and has been examined and certified by the AOTCB.

Occupational therapy aide.: Has been trained by the institution in which he or she works.

### Physical Therapy (PT)

Physical therapists work with patients disabled by strokes to help them regain motor control, strength, physical conditioning and mobility, and return to independent living.

:

Physical therapist.: Has completed at least 4 years of college, and many have completed a master's degree (6 years of higher education); all have successfully passed a State licensure examination.

Physical therapy assistant.: Has completed 2 years of education after high school.

Physical therapy aide.: Is trained by the institution in which he or she works.

### Psychology

Psycho logists assess the mental, cognitive, and emotional status of patients, work with the rehabilitation team to design treatment, and often provide treatment.

Clinical psychologist.: Has completed a doctoral program in psychology and a 1-year internship.

Neuropsychologist.: A specialized psychologist who emphasizes understanding and treatment of the cognitive, psychological, and behavioral problems that occur after damage to specific areas of the brain.

### Recreational Therapy

Recreational therapists work with the rehabilitation team to assess functional and leisure abilities and to promote recovery through physical conditioning and leisure activities. Certification is offered by the National Council for Therapeutic Recreation Certification (NCTRC).

Certified therapeutic recreation specialist (CTRS).: Has completed 4 years of college with a degree in therapeutic recreation (recreational therapy) or a degree in recreation with an emphasis in therapeutic recreation, has completed a supervised recreational therapy field-work placement of 36 hours, and has passed the national certification examination administered by NCTRC.

Certified therapeutic recreation assistant (CTRA).: Has completed a 2-year or associate degree with a major in recreation or therapeutic recreation; a 10-week field placement may be required.

### Rehabilitation Nursing

Rehabilitation nurses are specifically trained by experience, continuing education, or graduate education to provide nursing services to patients disabled by strokes or other chronic diseases, with the goals of restoring and maintaining health, function, independence, and quality of life for the patient and family, and the cost-effective use of resources.

Registered nurse (RN).: Has completed a 2- or 3-year hospital-based program in nursing or a 2- or 4-year college program in nursing, and has successfully passed an examination by the State board of nursing.

Certified rehabilitation registered nurse (CRRN).: A registered nurse (RN) with at least 2 years of experience in rehabilitation nursing who has been examined and certified by the Rehabilitation Nursing Certification Board.

Nurse practitioner.: An RN who has met advanced educational and clinical practice requirements. A nurse practitioner conducts physical examinations, takes medical histories, orders and interprets laboratory tests and x-rays, diagnoses and treats common illnesses; and, in 43 States, prescribes medications.

### Social Work

Social workers are integral members of the rehabilitation team with special responsibilities for working with patients and families to evaluate community and family resources, obtain necessary community services, and facilitate discharge planning. Social workers will also often provide counseling and education.

Licensed clinical social worker (LCSW).: Typically, has completed 4 years of college and a 2-year master's program in social work (MSW) and has been licensed by a State examining board. Requirements vary by State.

### Speech Therapy

Speech-language pathologists work with patients with aphasia, dysarthria, and dysphagia.

Speech-language pathologist (SLP).: Has completed 4 years of college, a master's degree in speech-hearing-language pathology, 375 hours of supervised clinical observation, and a 36-week clinical fellowship. SLPs obtain a Certificate of Clinical Competence (CCC) from the American Speech-Language-Hearing Association (ASHA).

### Dietitians

The dietitian assesses the nutritional status of the patient and provides diet therapy, counseling, or specialized nutritional supplements.

Registered dietitian.: Has completed a baccalaureate degree granted by a U.S. regionally accredited college or university; has met current academic requirements as approved by the American Dietetic Association; has successfully completed the Registration Examination for Dietitians; and has accrued 75 hours of approved continuing education every 5 years.

## General Terms in Stroke Rehabilitation

Activation.: Stimulating the nervous system through encouraging the patient who has suffered a stroke to become mentally and physically active.

Activities of daily living (ADL).: Basic daily activities such as eating, grooming, toileting, and dressing.

Acute care hospital.: A hospital that is organized and staffed to provide care for patients with acute medical problems.

Acute rehabilitation.: Term used by some sources to denote intense rehabilitation in an inpatient rehabilitation facility.

Ambulation.: The act of walking.

Assessment.: Determining the scope, importance, and value of a medical or psychological condition, social or environmental situation, or treatment.

Biofeedback.: Use of visual or auditory feedback on the state of a physiologic function (such as heart rate) or the position of a part of the body (such as the arm or leg) with the purpose of helping the individual gain better control over the function or position.

Caregiver.: A person who provides direct support for a disabled individual, usually in the home.

Comorbidity.: One or more additional chronic diseases in an individual who has suffered a stroke, such as heart or lung disease.

Compensation.: The ability of an individual with disabilities from stroke to perform a task (or tasks) either using the impaired limb with an adapted (different) approach or using the unaffected limb to perform the task; an approach to rehabilitation in which the patient is taught to adapt to and offset residual disabilities.

Comprehensive rehabilitation.: Rehabilitation involving a full array of rehabilitation services and disciplines (physical therapy, occupational therapy, speech and language pathology, recreational therapy, mental health services, etc.).

Continence.: The ability to control bodily functions, especially urinary bladder and bowel function.

Counseling.: Supportive and educational interventions aimed at assisting the patient or family in identifying key issues and problem solving around them.

Deconditioning.: The loss of cardiovascular or physical fitness as a result of inactivity.

Deficit.: Loss of ability. In the case of a stroke, a loss of neurological function.

Disability.: Reduced ability or lack of ability of an individual to perform an activity in daily life.

Family.: Relatives or friends who live with or are close to the patient.

Forced use.: Use of an impaired limb encouraged by restraining the unaffected limb and, hence, preventing it from taking over performance of required tasks.

Functional electrical stimulation.: Bursts of electrical stimulation applied to the nerves or muscles affected by the stroke, with the goal of strengthening muscle contraction and improving motor control. Lower intensities (transcutaneous electrical nerve stimulation, or TENS) are also used for pain control.

Functional limitation.: Reduced ability or lack of ability to perform an action or activity in the manner or within the range considered to be normal.

Gait symmetry.: A normal walking pattern, in which the movements of one leg are mirrored by similar movements of the other leg.

Handicap.: A disadvantage resulting from an impairment or disability that limits or prevents fulfillment of a role that is normal for the affected individual.

Impairment.: The loss or abnormality of physical or psychological capacities.

Independent.: Able to perform all usual functions without assistance or supervision.

Inpatient.: An individual who is receiving care while being housed in a medical facility.

Institutionalization.: Custodial care of a mentally or physically dependent individual in a long-term care facility.

Instrumental activities of daily living (IADL).: Complex activities required for independent living, such as using a telephone, home management, cooking, use of public transportation, or financial management.

Intense rehabilitation.: Generally interpreted to mean rehabilitation involving 3 or more hours of acute physical, occupational, psychological, or speech and language therapy per day, 5 or more days per week.

Interdisciplinary treatment.: Treatment delivered to a patient by two or more medical or rehabilitative disciplines working collaboratively.

Medical stability.: Maintaining a constant health status in the face of diseases that threaten to upset it.

Mobility.: Ability to move freely.

Mobilization.: The act of getting a patient to move in bed, sit up, stand, and eventually walk.

Monitoring.: Repetitive checking of a patient's medical, neurological, and functional status.

Motor control.: Ability to control movements of the body.

Nursing facility.: A nursing home.

Orthoses.: Mechanical devices which apply pressure to parts of the body in order to support, correct, or aid function.

Outpatient.: A person receiving treatment in a hospital, clinic, or office without being hospitalized.

Pathology.: The interruption of, or interference with, normal bodily processes or structures by a disease process.

Postacute care.: Care delivered during convalescence after an acute illness.

Primary physician.: The physician who is responsible for the care of a patient's general medical problems and for the coordination of required specialty care; this is usually an internist, family practitioner, general practitioner, pediatrician, or obstetrician, but may be from any specialty.

Prophylaxis.: Treatments aimed at preventing disease.

Psychotherapy.: Interventions aimed at changing basic mental functions in an individual or organizational or transactional patterns in families.

Range of motion exercises.: Exercises during which joints are moved through their full degrees of flexion, extension, or rotation; range of motion exercise is "active" if the patient provides the power needed to move the joint or "passive" if the therapist provides the power.

Rehabilitation.: Restoration of the disabled person to self-sufficiency or maximal possible functional independence.

Rehabilitation hospital.: A freestanding hospital that is organized and staffed to provide intense and comprehensive inpatient rehabilitation.

Rehabilitation unit.: A distinct part of an acute care hospital that is organized and staffed to provide intense and comprehensive inpatient rehabilitation.

Reliability, interobserver.: A characteristic of assessment procedures or instruments that refers to the ability of different observers to obtain the same results in the same patient, provided that there has been no change in the patient's condition.

Reliability, test- retest.: A characteristic of assessment procedures or instruments that refers to the ability to obtain the same result at different points in time in a patient whose condition remains unchanged.

Remediation.: Approaches to rehabilitation that attempt to reduce the severity of neurological deficits.

Screening.: Examinations aimed at detecting medical conditions early in their course or before they become symptomatic, often with the purpose of implementing treatment that will prevent or ameliorate the problem.

Self-care.: Providing care for oneself, e.g., by performing one's own basic activities of daily living.

Sensibility.: The characteristics of an assessment procedure or instrument that refer to its reasonableness, importance, and ease of use.

Sensitivity.: The ability of an assessment procedure or instrument to detect clinically meaningful change.

Stroke unit.: A distinct part of an acute care hospital that is organized and staffed explicitly to provide care for patients with strokes.

Subacute rehabilitation.: A term used by some sources to refer to rehabilitation programs provided in nursing facilities.

## Medical and Neurological Terms

Agraphia.: Inability to express one's thoughts in writing.

Alexia.: Inability to understand written language.

Aneurysm.: A sac created by expansion of an artery, vein, or the heart.

Angiography.: A method of visualizing blood vessels by introducing a radiographic solution.

Anterior.: The front of the body or an organ.

Aphasia.: The loss of ability to communicate orally, through signs, or in writing, or the inability to understand such communications; the loss of language usage ability.

Apraxia.: A disorder of learned movement unexplained by deficits in strength, coordination, sensation, or comprehension.

Aspiration.: The act of inhaling solid or liquid materials into the lungs.

Astereognosis.: The inability to recognize or characterize objects by touch.

Ataxia.: A disorder in which muscles fail to move in a coordinated fashion.

Atrial fibrillation.: Rapid, irregular contraction of the atria of the heart that produces an irregular and often rapid ventricular rate.

Cardiac arrhythmia.: Irregular or abnormally slow or rapid beating of the heart.

Cardiovascular.: Pertaining to the heart and blood vessels.

Carotid artery.: A major artery in the neck that supplies blood to the head and brain.

Carotid endarterectomy.: Surgical removal of deposits in the walls of the carotid artery that, when present, have the effect of narrowing its lumen.

Cerebrum.: The main portion of the brain that includes the two cerebral hemispheres; this term is also used to refer to the entire brain.

Cognition/cognitive.: The process of knowing, including awareness, perception, reasoning, remembering, and problem solving.

Contracture.: A condition of fixed, high resistance to passive stretching that results from fibrosis and shortening of tissues that support muscles or joints.

Contralateral.: The opposite side of the body.

Coronary heart disease.: Deterioration of the heart caused by narrowing or clogging of arteries supplying the heart muscles, with resulting chest pain, heart attacks, and damage to the heart.

Decubitus ulcer.: Ulcer of the skin that forms as a result of prolonged pressure in patients confined to bed or wheelchair.

Deep vein thrombosis (DVT).: The clotting of blood in the deep veins of the leg or arm.

Dementia.: A mental disorder characterized by the loss of intellectual abilities and, frequently, personality changes due to deterioration of the brain. Alzheimer's disease is a frequent example.

Depression.: A mental state marked by feelings of despair, discouragement, and sadness.

Diagnosis.: Determining the exact nature of a specific disease.

Dysarthria.: A motor disorder that results in difficulty in motor speech mechanisms.

Dysphagia.: Difficulty swallowing.

Embolus/embolism.: A blood clot or other foreign substance that travels in the bloodstream to occlude an artery or vein.

Feeding gastrostomy.: A surgical opening in the stomach through which a person is fed.

Graphesthesia.: The sense by which figures or numbers drawn on the skin with a dull point are recognized.

Hemi-inattention.: A disturbance of a person's awareness of space on the side of the body opposite a stroke-causing lesion; often referred to as unilateral neglect.

Hemiparesis.: Muscular weakness or partial paralysis of one side of the body.

Hemiplegia.: Paralysis of one side of the body.

Hemorrhage.: Bleeding from the rupture of a blood vessel.

Hemorrhagic stroke.: A stroke resulting from the rupture of a blood vessel in the brain.

Homonymous hemianopsia.: Defective vision or blindness affecting the right or left halves of the visual fields of both eyes.

Hyperlipidemia.: The state of having elevated lipid levels in the blood.

Hypertension.: Elevated blood pressure.

Hypoarousal.: Below normal level of arousal.

Incontinence.: Lack of control over excretory functions (urination, bowels).

Infarction.: Death of a part of an organ, such as the brain, due to lack of oxygen and other nutrients.

Ipsilateral.: The same side of the body.

Intracerebral hemorrhage.: Hemorrhage into the cerebrum.

Ischemic stroke.: A stroke caused by an insufficient supply of blood and oxygen to a part of the brain.

Neurogenic bladder.: Abnormal function of the urinary bladder due to damage to the nervous system.

Neurology.: The branch of medicine that focuses on the study of the nervous system.

Occlusion.: Blockage.

Orthostatic hypotension.: Lowering of blood pressure with a change of body position from supine to erect.

Orthostatic tolerance.: The ability to maintain blood pressure while standing upright.

Perception.: Conscious mental recognition of a sensory stimulus.

Perseveration.: Involuntary and pathologic persistence of the same verbal response or motor activity regardless of the stimulus or its duration.

Pressure ulcer.: See decubitus ulcer.

Proprioception.: Perception of body movement or position.

Spasticity.: Abnormally increased tone in a muscle.

Stenosis.: Reduction in the size of a vessel or other opening.

Stereognosis.: The ability to perceive the nature and form of objects by the sense of touch.

Stroke.: An acute neurological dysfunction of vascular origin with symptoms and signs corresponding to the involvement of focal areas of the brain; alternatively, the rapid onset of a neurological deficit that persists for at least 24 hours and is caused by intracerebral or subarachnoid hemorrhage or the blockage of a blood vessel supplying or draining the brain.

Subarachnoid hemorrhage.: A hemorrhage in the space underneath the subarachnoid membrane that results in pressure on the brain or bleeding into the brain.

Thromboembolism.: An embolus that originates in and breaks away from a clot in one vessel to become lodged in another vessel.

Thrombosis.: The clotting of blood within a blood vessel.

Transient ischemic attack (TIA).: The rapid onset of a neurological deficit that clears spontaneously in minutes or a few hours.

Unilateral neglect.: A disturbance of a person's awareness of space on the side of the body opposite a stroke-causing lesion; often referred to as hemi-inattention.

## Terms in Research Studies on Stroke Rehabilitation

Case fatality rate.: The mortality rate in people affected with a given disease.

Control group.: A group of subjects in a research study to which results of an experimental treatment given to another group of subjects are compared.

Epidemiology.: The study of factors that influence the frequency and distribution of a disease in a population.

Experimental group.: The group of subjects in a research study which receives the experimental treatment.

Experimental study.: A study in which one treatment is compared to another.

Incidence.: The frequency of occurrence of new cases of a disease over a specified period of time.

Meta-analysis.: A technique for combining the results of several studies for the purpose of determining the net effects of related factors or treatments on a process or disease.

Multivariate analysis.: A set of statistical techniques for analyzing the individual and joint effects of a number of factors on the outcomes of the process or disease being studied.

Observational study.: A study that draws conclusions on the effects of factors or treatments by observing a group of subjects over a period of time.

Prospective study.: A study that depends on data collected prospectively from the time the study begins.

Randomized controlled trial (RCT).: A study in which subjects are assigned to the experimental or control group by a random selection procedure before data collection begins.

Retrospective study.: A study that depends on data collected earlier, usually for purposes unrelated to the study.

Risk factor.: A characteristic of the individual or environment that predisposes to the condition or disease of interest.