# Acronyms and Abbreviations

ADL: Activities of daily living AHCPR Agency for Health Care Policy and Research

BF: Biofeedback

CARF: Commission on Accreditation of Rehabilitation Facilities

CRRN: Certified rehabilitation registered nurse

CT: Computed tomography

CTRS: Certified therapeutic rehabilitation specialist

DVT: Deep vein thrombosis

FES: Functional electrical stimulation

HCFA: Health Care Financing Administration

IADL: Instrumental activities of daily living

JCAHO: Joint Commission on Accreditation of Healthcare Organizations

LCSW: Licensed clinical social worker

LOA: Leave of absence

MRI: Magnetic resonance imaging

NIH: National Institutes of Health

OT: Occupational therapy

OTR: Registered occupational therapist

PT: Physical therapy, physical therapist

PVR: Postvoid residual

RCT: Randomized controlled trial

SLP: Speech-language pathologist

WHO: World Health Organization