# References

Adams HP, Bendixen BH, Kappelle J, Biller J, Love BB, Gordon DL, Marsh EE, and the TOAST Investigators. Classification of subtype of acute ischemic stroke. Stroke. 1993;24:35-41. [pmid: 7678184].
Adams HP, Brott TG, Crowell RM, Furlan AJ, et al., editors. Management of patients with acute ischemic stroke, Dallas (TX): American Heart Association;1994
Ahlsio B, Britton M, Murray V, Theorell T. Disablement and quality of life after stroke Stroke 1984 Sep-Oct 15(5):886 90 6236588
American Heart Association. Heart and stroke facts, Dallas (TX): American Heart Association;1991
Andersen G, Verstergaard K, Lauritzen L. Effective treatment of poststroke depression with the selective serotonin reuptake inhibitor citalopram. Stroke. 1994;25:1099-109. [pmid: 8202964].
Anderson S, Tranel D. Awareness of disease states following cerebral infarction, dementia and head trauma: : standardized assessment. Clin Neuropsychologist. 1989;3:327-39.
Andrews K, Brocklehurst JC, Richards B, Laycock PJ. The rate of recovery from stroke--and its measurement Int Rehabil Med 1981 3(3):155 61 7333780
Asberg KH. Orthostatic tolerance training of stroke patients in general medical wards: An experimental study Scand J Rehabil Med 1989 21(4):179 85 2698505
Awad EA, Dykstra D. Treatment of spasticity by neurolysis In: Kottke FJ, Lehmann JF, editors. Krusen's handbook of physical medicine and rehabilitation. 4th ed, Philadelphia: WB Saunders;1990 p. 1154 61
Axelsson K, Asplund K, Norberg A, Alafuzoff I. Nutritional status in patients with acute stroke Acta Med Scand 1988 224(3):217 24 3239449
Axelsson K, Asplund K, Norberg A, Alafuzoff I. Nutritional status in patients with acute stroke: The implications of cognitive adaptation and social support ideas for coping with a stroke are discussed Soc Sci Med 1989 28(3):239 47 2919311
Bachman DL, Wolf PA, Linn RT, Knoefel JE, Cobb JL, Belanger AJ, White LR, D'Agostino RB. Incidence of dementia and probable Alzheimer's disease in a general population: the Framingham Study. Neurology. 1993;43:515-9. [pmid: 8450993].
Bamford J, Sandercock P, Dennis M, Warlow C. A prospective study of acute cerebrovascular disease in the community: the Oxfordshire Community Stroke Project: 2. Incidence, case fatality rates and overall outcome at one year of cerebral infarction, primary intracerebral and subarachnoid hemorrhage. J Neurology and Psychiatry. 1990;53:16-22.
Basmajian JV, Gowland C, Brandstater ME, Swanson L, Trotter J. EMG feedback treatment of upper limb in hemiplegic stroke patients: a pilot study Arch Phys Med Rehabil 1982 Dec 63(12):613 6 7149946
Basmajian JV, Gowland CA, Finlayson MA, Hall AL, Swanson LR, Stratford PW, Trotter JE, Brandsater ME. Stroke treatment: comparison of integrated behavioral-physical therapy vs traditional physical therapy programs Arch Phys Med Rehabil 1987 May 68(5 Pt 1):267 72 3579530
Basmajian JV, Kukulka CG, Narayan MG, Takebe K. Biofeedback treatment of foot-drop after stroke compared with standard rehabilitation technique: effects on voluntary control and strength Arch Phys Med Rehabil 1975 Jun 56(6):231 6 1137478
Basso A, Capitani E, Vignolo LA. Influence of rehabilitation on language skills in aphasic patients: A controlled study Arch Neurol 1979 Apr 36(4):190 6 426663
Beck AT, Steer RA. Beck Depression Inventory: manual Rev. ed., New York: NY Psychological Corporation;1987
Beck AT, Ward CH, Mendelson M, Mock J, Erbaugh J. An inventory for measuring depression. Arch Gen Psychiatry. 1961 Jun;4:561-71. [pmid: 13688369].
Bellavance A, for the Ticlopidine Aspirin Stroke Study Group. Efficacy of ticlopidine and aspirin for prevention of reversible cerebrovascular ischemic events: The Ticlopidine Aspirin Stroke Study. Stroke. 1993;24:1452-7. [pmid: 8378945].
Bennett CJ, Diokno AC. Clean intermittent self catheterization in the elderly Urology 1984 24(1):43 5 6740849
Ben-Yishay Y, Diller L, Gerstman L, Haas A. The relationship between impersistence, intellectual function and outcome of rehabilitation in patients with left hemiplegia Neurology 1968 Sep 18(9):852 61 5693678
Ben-Yishay Y, Gerstman L, Diller L, Haas A. Prediction of rehabilitation outcomes from psychometric parameters in left hemiplegics J Consult Clin Psychol 1970 Jun 34(3):436 41 5523452
Berg K. Measuring balance in the elderly: development and validation of an instrument MSc thesis McGill University;1988
Berg K. Measuring balance in the elderly: validation of an instrument PhD thesis McGill University;1993
Berg K, Maki B, Williams JI, Holliday P, Wood-Dauphinee S. A comparison of clinical and laboratory measures of postural balance in an elderly population. Arch Phys Med Rehabil. 1992;73:1073-83. [pmid: 1444775].
Berg K, Wood-Dauphinee S, Williams JI, Gayton D. Measuring balance in the elderly: preliminary development of an instrument. Physiother Can. 1989;41:304-11.
Berg K, Wood-Dauphinee S, Williams JI, Maki B. Measuring balance in the elderly: validation of an instrument Can J Public Health 1992 Jul-Aug Suppl 2: S7 11 1468055
Berglund K, Fugl-Meyer AR. Upper extremity function in hemiplegia. A cross-validation study of two assessment methods Scand J Rehabil Med 1986 18(4):155 7 3810081
Bergner M, Bobbitt RA, Carter WB, Gilson BS. The Sickness Impact Profile: development and final revision of a health status measure. Med Care. 1981;19:787-805. [pmid: 7278416].
Bergstrom G, Aniansson A, Bjelle A, Grimby G, Lundgre[n-Lindquist] B, Svanborg A. Functional consequences of joint impairment at age 79. Scand J Rehab Med. 1985;17:183-90.
Bergstrom N, Braden BJ, Laguzza A, Holman V. The Braden Scale for predicting pressure sore risk Nurs Res 1987 Jul-Aug 36(4):205 10 3299278
Bergstrom N, Demuth PJ, Braden BJ. A clinical trial of the Braden Scale for predicting pressure sore risk Nurs Clin North Am 1987 Jun 22(2):417 28 3554150
Beyerman K.In: Mclane AM, editor. Conference on the classification of nursing diagnosis. 7th ed, St Louis (MO): CV Mosby;1987
Bishop DS, Epstein NB, Keitner GI, Miller IW, Srinivasan SV. Stroke: morale, family functioning, health status, and functional capacity Arch Phys Med Rehabil 1986 Feb 67(2):84 7 3954570
Bjork DT, Pelletier LL, Tight RR. Urinary tract infections with antibiotic resistant organisms in catheterized nursing home patients Infect Control 1984 5(4):173 6 6562089
Blazer D, Hughes D, George L. The epidemiology of depression in an elderly community population. Gerontologist. 1987;27:281-7. [pmid: 3609795].
Bobath B. Adult hemiplegia: evaluation and treatment 3rd ed, London: William Hinneman Medical Books;1990
Bobath B. Hemiplegia: evaluation and treatment 2nd ed, Oxford; Boston: Butterworth-Heinemann;1978
Bolla-Wilson K, Robinson RG, Starkstein SE, Boston J, Price TR. Lateralization of dementia of depression in stroke patients Am J Psychiatry 1989 May 146(5):627 34 2712168
Bonita R, Beaglehole R. Recovery of motor function after stroke Stroke 1988 Dec 19(12):1497 500 3201508
Bonita R, Beaglehole R, North JDK. Event, incidence and case fatality rates of cerebrovascular disease in Auckland, New Zealand. Am J Epidemiol. 1984;120:236-43. [pmid: 6465121].
Borgman MF, Passarella PM. Nursing care of the stroke patient using Bobath principles: An approach to altered movement Nurs Clin North Am 1991 Dec 26(4):1019 35 1945934
Borkman T. Self-help groups at the turning point: emerging egalitarian alliances with the formal health care system? Am J Community Psychol 1990 18(2):321 32 2198799
Boston area anticoagulation trial for atrial fibrillation: The effect of low-dose warfarin on the risk of stroke in patients with non-rheumatic atrial fibrillation. N Engl J Med. 1990;323:1504-11.
Bounds JV, Wiebers DO, Whisnant JP, Okazaki H. Mechanisms and timing of deaths from cerebral infarction. Stroke. 1981;12:474-7. [pmid: 7314170].
Bowman BR, Baker LL, Waters RL. Positional feedback and electrical stimulation: an automated treatment for the hemiplegic wrist Arch Phys Med Rehabil 1979 Nov 60(11):497 502 508075
Braden BJ. [Bergstron N.] Clinical utility of the Braden Scale for predicting pressure sore risk Decubitus 1989 Aug 2(3):44 6, 50-1
Braden B, Bergstrom N. Braden Scale for predicting pressure ulcers in adults: Pressure ulcers in adults; prediction and prevention Clinical practice guideline, no. 3. AHCPR publication no. 92-0047, Rockville (MD): Agency for Health Care Policy and Research. May 1992 p. 16 7
Braden B, Bergstrom N. A conceptual schema for the study of the etiology of pressure sores Rehabil Nurs 1987 Jan-Feb 12(1):8 12 3643620
Branch LG, Jette AM. The Framingham Disability Study: I. Social disability among the aging. Am J Public Health. 1981;71:1202-10. [pmid: 7294261]. [pmcid: 1619908].
Brandstater M, Basmajian J. Stroke rehabilitation, Baltimore (MD): Williams & Wilkins;1987
Brandstater ME, de Bruin H, Gowland C, Clark BM. Hemiplegic gait: analysis of temporal variables Arch Phys Med Rehabil 1983 Dec 64(12):583 7 6661021
Brandstater ME, Roth EJ, Siebens HC. Venous thromboembolism in stroke: literature review and implications for clinical practice Arch Phys Med Rehabil 1992 73(Suppl):379 89
Bray GP, DeFrank RS, Wolfe TL. Sexual functioning in stroke survivors Arch Phys Med Rehabil 1981 Jun 62(6):286 8 7235924
Brocklehurst JC, Andrews K, Richards B, Laycock PJ. Incidence and correlates of incontinence in stroke patients J Am Geriatr Soc 1985 Aug 33(8):540 2 4019999
Brocklehurst JC, Morris P, Andrews K, Richards B, Laycock P. Social effects of stroke Soc Sci Med 1981 Jan 15(A):35 9
Broderick JP, Phillips SJ, Whisnant JP, O'Fallon WM, Bergstralh EJ. Incidence rates of stroke in the eighties: the end of the decline in stroke. Stroke. 1989;20:577-82. [pmid: 2718196].
Brooke MM, Questad KA, Patterson DR, Valois TA. Driving evaluation after traumatic brain injury. Am J Phys Med Rehabil. 1992;71:177-82. [pmid: 1627283].
Brott T, Adams HP, Olinger CP, Marler JR, Barsan WG, Biller J, Spilker J, Holleran R, Eberle R, Hertzberg V, et al. Measurements of acute cerebral infarction: a clinical examination scale Stroke 1989 Jul 20(7):864 70 2749846
Burnside IG, Tobias HS, Bursill D. Electromyographic feedback in the remobilization of stroke patients: a controlled trial Arch Phys Med Rehabil 1982 May 63(5):217 22 7041850
Butfield E, Zangwill O. Re-education in aphasia: a review of 70 cases. J Neurol Neurosurg Psychiatry. 1946:75-9.
Butland RJA, Pang J, Gross ER, Woodcock AA, Geddes DM. Two, six and twelve minute walking tests in respiratory disease. BMJ. 1982;284:1604-8. [pmid: 6211217]. [pmcid: 1498550].
Butter CE, Kirsh N. Kirsch N. Combined and separate effects of eye patching and visual stimulation on unilateral neglect following stroke. Arch Phys Med Rehabil. 1992;73:1133-9. [pmid: 1463376].
Butter CM, Kirsch NL, Reeves G. The effect of lateralised stimuli on unilateral spatial neglect following right hemisphere lesions. Restorative Neurology and Neuroscience. 1990;2:39-46. [pmid: 21551871].
Byles J, Bryne C, Boyle M, Offord D. Ontario child health study: reliability and validity of the general functioning subscale of the McMaster Family Assessment Device. Family Process. 1988;27:97-104. [pmid: 3360100].
Byng S. Sentence processing deficits: theory and therapy. Cognitive Neuropsychology. 1988;5:629-76.
Carey JR. Manual stretch: effect on finger movement control and force control in stroke subjects with spastic extrinsic finger flexor muscles Arch Phys Med Rehabil 1990 Oct 71(11):888 94 2222157
Carey RG, Posavac EJ. Program evaluation of a physical medicine and rehabilitation unit: a new approach Arch Phys Med Rehabil 1978 Jul 59(7):330 7 687042
Carr JH, Shepherd RB. A motor learning model for stroke rehabilitation Physiotherapy 1989 Jul 75(7):372 80
Carr JH, Shepherd RB, Nordholm L, Lynne D. Investigation of a new motor assessment scale for stroke patients Phys Ther 1985 Feb 65(2):175 80 3969398
Carter LT, Caruso JL, Languirand MA, Berard MA. Cognitive skill remediation in stroke and non-stroke elderly Clinical Neuropsychology 1980 II(3):109 13
Carter LT, Howard BE, O'Neil WA. Effectiveness of cognitive skill remediation in acute stroke patients Am J Occup Ther 1983 May 37(5):320 6 6869493
Chan F, Lynch R, Dial J, Wong D, Kates D. Applications of McCarron-Dial System in vocational evaluation: an overview of its operational framework and empirical findings Vocational Eval and Work Adjustment Bull 1993 26(2):57 65
Charness A. Stroke/head injury: a guide to functional outcomes in physical therapy management, Rockville (MD): Aspen Publishers;1986
Chen MY, Ott DJ, Peele VN, Gelfand DW. Oropharynx in patients with cerebrovascular disease: evaluation with videofluoroscopy Radiology 1990 Sep;176(3):641 3 2389021
Chenelly S.In: Dittmer S, editor. Rehabilitation nursing: process and application, St. Louis (MO): CV Mosby;1989
Clagett GP, Anderson FA, Levine MN, Salzman EW, Wheeler HB. Prevention of venous thromboembolism Chest 1992 October 102(4)(Suppl):391S 407S 1395824
Clarke M, Kadhom HM. The nursing prevention of pressure sores in hospital and community patients J Adv Nurs 1988 May 13(3):365 73 3417931
Collen FM, Wade DT, Robb GF, Bradshaw CM. The Rivermead Mobility Index: a further development of the Rivermead Motor Assessment. Int Disabil Stud. 1991;13:50-4. [pmid: 1836787].
Collin C, Wade D. Assessing motor impairment after stroke: a pilot reliability study J Neurol Neurosurg Psychiatry 1990 Jul 53(7):576 9 2391521 488133
Connolly SJ, Laupacis A, Gent M, Roberts RS, Cairns JA, Joyner C. Canadian Atrial Fibrillation Anticoagulant (CAFA) Study. J Am Coll Cardiol. 1991;18:349-55. [pmid: 1856403].
Cooper R, Sempos C, Hsieh SC, Kover MG. Slowdown in the decline of stroke mortality in the United States, 1978-1986. Stroke. 1990;;21:1274-9. [pmid: 2396262].
Corcoran PJ, Jebsen RH, Brengelmann GL, Simons BC. Effects of plastic and metal leg braces on speed and energy cost of hemiparetic ambulation Arch Phys Med Rehabil 1970 Feb 51(2):69 77 5437126
Coslett HB, Heilman KM. Male sexual function: Impairment after right hemisphere stroke Arch Neurol 1986 Oct 43(10):1036 9 3753264
Cote R, Battista RN, Wolfson C, Boucher J, Adam J,Hachinski V. The Canadian Neurological Scale: validation and reliability assessment. Neurology. 1989 May;39:638-43. [pmid: 2710353].
Cote R, Hachinski VC, Shurvell BL, Norris JW, Wolfson C. The Canadian Neurological Scale: a preliminary study in acute stroke. Stroke. 1986;17:731-7. [pmid: 3738958].
Cozean CD, Pease WS, Hubbell SL. Biofeedback and functional electrical stimulation in stroke rehabilitation. Arch Phys Med Rehabil. 1988;69:401-5. [pmid: 3288172].
Crowe NM, Athelestan GT. Functional assessment in rehabilitation: systematic approach to diagnosis and goal setting. Arch Phys Med Rehabil. 1981;62:229-305. [pmid: 6972207].
Culebras A. Neuroanatomic and neurologic correlates of sleep disturbances Neurology 1992 Jul 42(Suppl 6):19 27 1630635
Cushman LA. Secondary neuropsychiatric complications in stroke: implications for acute care Arch Phys Med Rehabil 1988 Oct 69(10):877 9 3178456
Davis G, Wilcox J. Adult aphasia rehabilitation: Applied pragmatics, San Diego (CA): College Hill;1985
DeJong G, Branch LG. Predicting the stroke patient's ability to live independently Stroke 1982 Sep-Oct 13(5):648 55 7123598
Demeurisse G, Demol O, Robaye E. Motor evaluation in vascular hemiplegia Eur Neurol 1980 19(6):382 9 7439211
De Weerdt W, Harrison M. Measuring recovery of arm-hand function in stroke patients: a comparison of the Brunnstrom-Fugl-Meyer test and the action research arm test Physiother Can 1985 37(2):65 70
Denes G, Semenza C, Stoppa E, Lis A. Unilateral spatial neglect and recovery from hemiplegia: a follow-up study Brain 1982 Sep 105(Pt 3):543 52 7104665
Depression Guideline Panel. Depression in primary care: Vol. 2. Treatment of major depression Clinical practice guideline no. 5 (AHCPR Publication no. 93-0551), Rockville (MD): Agency for Health Care Policy and Research;1993
Dettmann MA, Linder MT, Sepic SB. Relationships among walking performance, postural stability, and functional assessments of the hemiplegic patient Am J Phys Med 1987 Apr 66(2):77 90 3578493
DeVincenzo DK, Watkins S. Accidental falls in a rehabilitation setting Rehabil Nurs 1987 Sep-Oct 12(5):248 52 3671870
Dickstein R, Hocherman S, Pillar T, Shaham R. Stroke rehabilitation: Three exercise therapy approaches Phys Ther 1986 Aug 66(8):1233 8 3737695
DiIorio C, Price M. Swallowing: an assessment guide. Am J Nurs. 1990 Jul:38-46.
Diller L, Weinberg J. Evidence for accident-prone behavior in hemiplegic patients Arch Phys Med Rehabil 1970 Jun 51(6):358 63 5423806
Diller L, Weinberg J. Response styles in perceptual retraining In: Gordon WA, editor. Advances in stroke rehabilitation, Boston (MA): Andover Medical Pub;1993 162 82
Dombovy ML. Rehabilitation and the course of recovery after stroke In: Whisnant J, editor. Stroke: populations, cohorts, and clinical trials, Oxford; Boston: Butterworth-Heinemann;1993
Dombovy ML, Basford JR, Whisnant JP, Bergstralh EJ. Disability and use of rehabilitation services following stroke in Rochester, Minnesota, 1975-1979 Stroke 1987 Sep-Oct 18(5):830 6 3629639
Dombovy ML, Sandok BA, Basford JR. Rehabilitation for stroke: a review Stroke 1986 May-Jun 17(3):363 9 2940735
Doolittle ND. The experience of recovery following lacunar stroke Rehabil Nurs 1992 17(3):122 5 1585040
Downhill JE, Robinson RG. Longitudinal assessment of depression and cognitive impairment following stroke J Nerv Ment Dis 1994 Aug 182(8):425 31 8040651
Drummond A. Leisure activity after stroke Int Disabil Stud 1990 12(4):157 60 2103567
Duke University Center for the Study of Aging and Human Development. Multidimensional functional assessment: the OARS methodology, Durham (NC): Duke University;1978
Duncan PW. Contemporary management of motor control problems: proceedings of the II Step Conference Chapter 21, Stroke: physical therapy assessment and treatment, Alexandria (VA): Foundation for Physical Therapy;1992
Duncan PW, Chandler J, Studenski S, Hughes M, Prescott B. How do physiological components of balance affect mobility in older men? Arch Phys Med Rehabil 1993 Dec 74(74):1343 9 8259903
Duncan PW, Propst M, Nelson SG. Reliability of the Fugl-Meyer assessment of sensorimotor recovery following cerebrovascular accident Phys Ther 1983 Oct 63(10):1606 10 6622535
Dyken ML, Wolf PA, Barnett HJM, Bergan JJ, Hass WK, Kannel WB, Kuller L, Kurtzke JF, Sundt TM. Risk factors in stroke: a statement for physicians by the Subcommittee on Risk Factors and Stroke Council. Stroke. 1984;15:1105-11.
Eastwood MR, Rifat SL, Nobbs H, Ruderman J. Mood disorders following cerebrovascular accident. Br J Psychiatry. 1989;154:195-200. [pmid: 2528388].
Ebrahim S, Barer KD, Nouri F. Affective illness after stroke. Br J Psychiatry. 1987;151:52-60. [pmid: 2960413].
Emick-Herring B, Wood P. A team approach to neurologically based swallowing disorders Rehabil Nurs 1990 May-Jun 15(3):126 32 2343174
Engel BT, Burgio LD, McCormick KA, et al. Behavioral treatment of incontinence in the long-term care setting J Am Geriatr Soc 1990 38(3):361 3 2107245
Epstein NB, Baldwin LM, Bishop DS. The McMaster Family Assessment Device J Marital Fam Ther 1983 Apr 9(2):171 80
Ernst E. A review of stroke rehabilitation and physiotherapy Stroke 1990 Jul 21(7):1081 4 2195716
European Carotid Surgery Trialists Collaborative Group. MRC European carotid surgery trial: interim results for symptomatic patients with severe (79-99%) or with mild (0-29%) carotid stenosis. Lancet. 1991;337:1235-43. [pmid: 1674060].
Evans RL. Caregiver compliance and feelings of burden in poststroke home care. Psychol Rep. 1986;59:1013-14. [pmid: 3809333].
Evans RL, Bishop DS, Dusley RT. Ousley RT. Providing care to persons with disability: effect on family caregivers Am J Phys Med Rehabil 1992 71(3)140 4 1385711
Evans RL, Bishop DS, Haselkorn JK. Factors predicting satisfactory home care after stroke. Arch Phys Med Rehabil. 1991 Feb;72:144-7. [pmid: 1991016].
Evans RL, Bishop DS, Matlock AL, Stranahan S, Smith GG, Halar EM. Family interaction and treatment adherence after stroke Arch Phys Med Rehabil 1987a Aug 68(8):513 7 3619615
Evans RL, Bishop DS, Matlock AL, Stranahan S, Noonan C. Predicting poststroke family function: a continuing dilemma. Psychol Rep. 1987b;60:691-5. [pmid: 3615714].
Evans RL, Hendricks RD, Lawrence-Umlauf KV, Bishop DS. Timing of social work intervention and medical patients' length of hospital stay. Health Soc Work. 1989;Nov:277-82. [pmid: 2513270].
Evans RL, Matlock AL, Bishop DS, Stranahan S, Pederson C. Family intervention after stroke: does counseling or education help? Stroke 1988 Oct 19(10):1243 9 3176084
Evans R, Noonan WC. Does caregiver anxiety influence adjustment to stroke?. Arch Phys Med Rehab. 1988;69.
Ezekowitz MD, Bridgers SE, James KE, Carliner NH, Colling CL, Gornick CC, Krause-Steinrauf H, Kurtzke JF, Nazarian SM, Radford MJ, et al. Warfarin in the prevention of stroke associated with nonrheumatic atrial fibrillation. N Engl J Med. 1992;327:1406-12. [pmid: 1406859].
Feigenson JS, Gitlow HS, Greenberg SD. The disability oriented rehabilitation unit: a major factor influencing stroke outcome Stroke 1979 Jan-Feb 10(1):5 8 155326
Feinstein AR. Clinimetrics, New Haven (CT): University Press;1987
Feldman DJ, Lee PR, Unterecker J, Lloyd K, Rusk HA, Toole A. A comparison of functionally orientated medical care and formal rehabilitation in the management of patients with hemiplegia due to cerebrovascular disease. J Chronic Dis. 1962;15:197-310.
Ferrucci L, Bandinelli S, Guralnik JM, Lamponi M, Bertini C, Falchini M, Baroni A. Recovery of functional status after stroke: : a postrehabilitation follow-up study. Stroke. 1993;24:200-5. [pmid: 8421819].
Fiatarone MA, Marks EC, Ryan ND, Meredith CN, Lipsitz LA, Evans WJ. High-intensity strength training in nonagenarians: Effects on skeletal muscle JAMA 1990 Jun 13 263(22):3029 34 2342214
Folstein MF, Folstein SE, McHugh PR. Mini-mental state: a practical method for grading the cognitive state of patients for the clinician J Psychiatr Res 1975 Nov 12(3):189 98 1202204
Foulkes MA, Wolf PA, Price TR, Mohr JP, Hier DB. The stroke data bank: design, methods, and baseline characteristics Stroke 1988 May 19(5):547 54 3363586
Friedland J, McColl M. Social support and psychosocial dysfunction after stroke: buffering effects in a community sample Arch Phys Med Rehabil 1987 Aug 68(8):475 80 3619609
Friedland JF, McColl M. Social support intervention after stroke: results of a randomized trial Arch Phys Med Rehabil 1992 Jun 73(6):573 81 1622308
Fristad MA. A comparison of the McMaster and Circumplex family assessment instruments J Marital Fam Ther 1989 15(3):259 69 21118457
Fugl-Meyer AR, Jaasko L, Leyman I, Olsson S, Steglind S. The post stroke hemiplegic patient: I. A method for evaluation of physical performance. Scand J Rehabil Med. 1975;7:13-31. [pmid: 1135616].
Fullerton KJ, McSherry D, Stout RW. Albert's test: a neglected test of perceptual neglect Lancet 1986 Feb 22 1(8478):430 2 2868349
Galski T, Bruno RL, Zorowitz R, Walker J. Predicting length of stay, functional outcome, and aftercare in the rehabilitation of stroke patients: The dominant role of higher-order cognition Stroke 1993 Dec 24(12):1794 800 8248957
Garlinghouse NM. Sexuality of male cerebral vascular accident victims Sex and Disabil 1987 Summer 8(2):67 72
Garraway WM, Akhtar AJ, Hockey L, Prescott RJ. Management of acute stroke in the elderly: follow-up of a controlled trial. BMJ. 1980 Sep 27;281:827-9. [pmid: 7000279].
Garraway WM, Akhtar AJ, Prescott RJ, Hockey L. Management of acute stroke in the elderly: preliminary results of a controlled trial BMJ 1980 Apr 12 280(6220):1040 3 6996779
Garraway WM, Akhtar AJ, Smith DL, Smith ME. The triage of stroke rehabilitation J Epidemiol Community Health 1981 Mar 35(1):39 44 7021747 1052118
Garraway WM, Walton MS, Akhtar AJ, Prescott RJ. The use of health and social services in the management of stroke in the community: : results from a controlled trial Age Ageing 1981 May 10(2):95 104 6264761
Garraway WM, Whisnant JP, Drury I. The changing pattern of survival following stroke. Stroke. 1983;14:699-703. [pmid: 6658952].
Gelber DA, Good DC, Laven LJ, Verhulst SJ. Causes of urinary incontinence after acute hemispheric stroke Stroke 1993 24(3):378 82 8446973
Gerson LW. The incidence of pressure sores in active treatment hospitals Int J Nurs Stud 1975 12(4):201 4 1046014
Gillum RF. Strokes in blacks. Stroke. 1988;19:1-6. [pmid: 3276035].
Glanz M, Klawansky S, Stason W, Berkey C, Shah N, Phan H, Chalmers TC. Biofeedback therapy in post-stroke rehabilitation: A meta-analysis of the randomized control trials. Unpublished paper. 1994a.
Glanz M, Klawansky S, Stason W, Berkey C, Shah N, Phan H, Chalmers T. Functional electrical stimulation in post-stroke rehabilitation: a meta-analysis of randomized control trials. Unpublished paper. 1994b.
Glass TA, Matchar DB, Belyea M, Feussner JB. Impact of social support on outcome in first stroke. Stroke. 1993;24:64-70. [pmid: 8418553].
Glasser L. Effects of isokinetic training on the rate of movement during ambulation in hemiparetic patients Phys Ther 1986 May 66(5):673 6 3703931
Goldman HH, Skodol AE, Lave TR. Revising Axis V for DSM-IV: a review of measures of social functioning Am J Psychiatry 1992 Sep 149(9):1148 56 1386964
Goldstein LB. Basic and clinical studies of pharmacologic effects on recovery from brain injury J Neural Transplant Plast 1993 Jul-Sep 4(3):175 92 8018750
Goldstein LB, Bertels C, Davis JN. Interrater reliability of the NIH stroke scale Arch Neurol 1989 Jun 46(6):660 2 2730378
Goodglass H, Kaplan E. The assessment of aphasia and related disorders Chapter 4, Test procedures and rationale. Manual for the BDAE, Philadelphia: Lee and Febiger;1972
Goodglass H, Kaplan E. Boston Diagnostic Aphasia Examination (BDAE), Philadelphia: Lea and Febiger;1983
Gordon J. Assumptions underlying physical therapy intervention: theoretical and historical perspectives In: Carr J, Shepherd RB, Gordon J, et al., editors. Movement science foundations for physical therapy in rehabilitation, Rockville (MD): Aspen Publishers Inc.;1987. p. 1 30
Gordon WA. Treatment of affective deficits in stroke rehabilitation: : Final report National Institutes of Health;NS 24608 1992
Gordon WA, Diller L. Stroke: coping with a cognitive deficit In: Burish TG, Bradley LA, editors. Coping with chronic disease, New York: Academic Press;1983
Gordon WA, Hibbard MR, Egelko S, Diller L, Shaver MS, Lieberman A, Ragnarsson K. Perceptual remediation in patients with right brain damage: a comprehensive program Arch Phys Med Rehabil 1985 Jun 66(6):353 94 4004531
Gordon WA, Hibbard MR, Egelko S, Riley E, Simon D, Ross E, Leiberman A. Issues in the diagnosis of post stroke depression. Rehab Psychol. 1991;36:71-87.
Granger CV. A conceptual model for functional assessment In: Granger CV, Gresham GE, editors. Functional assessment in rehabilitation medicine, Baltimore: Williams & Wilkins;1984 p. 14 25
Granger CV, Albrecht GL, Hamilton BB. Outcome of comprehensive medical rehabilitation: measurement by PULSES profile and the Barthel Index Arch Phys Med Rehabil 1979 Apr 60(4):145 54 157729
Granger CV, Dewis LS, Peters NC, Sherwood CC, Barrett JE. Stroke rehabilitation: analysis of repeated Barthel Index measures Arch Phys Med Rehabil 1979 Jan 60(1):14 7 420565
Granger CV, Hamilton BB. Measurement of stroke rehabilitation outcome in the 1980s Stroke 1990 Sep 21(Suppl II):1146 7
Granger CV, Hamilton BB. UDS Report: The uniform data system for medical rehabilitation report on the first admissions for 1990. Am J PHys Med Rehabil. 1992;71:108-13. [pmid: 1532719].
Granger CV, Hamilton BB, Keith RA, Zielezny M, Sherwin FS. Advances in functional assessment for medical rehabilitation Top Geriatr Rehabil 1986 1(3):59 74
Granger CV, Hamilton BB, Sherwin FS. Guide for the use of the uniform data set for medical rehabilitation Buffalo General Hospital, Uniform Data System for Medical Rehabilitation Project Office., New York;1986
Greenberg S, Fowler RS Jr. Kinesthetic biofeedback: a treatment modality for elbow range of motion in hemiplegia Am J Occup Ther 1980 Nov 34(11):738 43 6163362
Gresham GE, Phillips TF, Labi ML. ADL status in stroke: relative merits of three standard indexes Arch Phys Med Rehabil 1980 Aug 61(8):355 8 7406673
Gresham GE, Phillips TF, Wolf PA, McNamara PM, Kannel WB, Dawber TR. Epidemiologic profile of long-term stroke disability: the Framingham Study Arch Phys Med Rehabil 1979 60(11):487 91 508073
Gross JC. Bladder dysfunction after a stroke--it's not always inevitable J Gerontol Nurs 1990 Apr 16(4):20 5 2324432
State University of New York Guide for the uniform data set for medical rehabilitation (Adult FIM), version 4.0 Buffalo (NY) 14214: State University of New York at Buffalo;1993
Gwyther LP, George LK. Caregivers of for dementia patients: complex determinants of well-being and burden. Gerontologist. 1986;26:245-7. [pmid: 3721230].
Halstead L. Team care in chronic illness: a critical review of the literature of the past 25 years. Arch Phys Med Rehabil. 1976;57:507-11. [pmid: 985051].
Hamilton M. Development of a rating scale for primary depressive illness. Br J Soc Clin Psychol. 1967;6:278-96. [pmid: 6080235].
Hamilton M. A rating scale for depression. J Neurol Neurosurg Psychiatry. 1960;23:56-62. [pmid: 14399272].
Hamilton BB, Granger CV, Sherwin FS, Zielezny M, Tashman JS. A uniform national data system for medical rehabilitation In: Fuhrer MJ, editor. Rehabilitation outcomes: analysis and measurement, Baltimore: Brookes;1987 p. 137 147
Hamilton BB, Laughlin JA, Granger CV, Kayton RM. Interrater agreement of the seven level functional independence measure (FIM). Arch Phys Med Rehabil. 1991;72.
Hamrin E. II. Early activation in stroke: does it make a difference? Scand J Rehabil Med 1982a 14(3):101 9 7134909
Hamrin E. III. One year after stroke: a follow-up of an experimental study Scand J Rehabil Med 1982b 14(3):111 6 7134910
Harmsen P, Tsipogianni A, Wilhelmsen L. Stroke Incidence rates were unchanged, while fatality rates declined, during 1971-1987 in Goteborg, Sweden. Stroke. 1992;23:1410-15. [pmid: 1412576].
Hartman J, Landau WM. Comparison of formal language therapy with supportive counseling for aphasia due to acute vascular accident. Arch Neurol. 1987;44:646-9. [pmid: 3579683].
Harvey RF, Jellinek HM. Functional performance assessment: a program approach. Arch Phys Med Rehabil. 1981;62:456-61. [pmid: 7283689].
Hayes SH, Carroll SR. Early intervention care in the acute stroke patient Arch Phys Med Rehabil 1986 May 67(5):319 21 3707317
Helm-Estabrooks N, Emery P, Albert ML. Treatment of aphasic perseveration (TAP) program: A new approach to aphasia therapy. Arch Neurol. 1987;44:1253-5. [pmid: 3675258].
Helm-Estabrooks N, Fitzpatrick P, Barresi B. Visual action therapy for global aphasia. J Speech Hear Disord. 1982;44:385-9. [pmid: 6194372].
Hertanu JS, Demopoulos JT, Yang WC, Calhoun WF, Fenigstein HA. Stroke rehabilitation: correlation and prognostic value of computerized tomography and sequential functional assessments Arch Phys Med Rehabil 1984 Sep 65(9):505 8 6477080
Hibbard MR, Gordon WA. The comprehensive psychological assessment of individuals with stroke J Neurol Rehabil 1992 2(4):9 20
Hibbard MR, Gordon WA, Stein DN, et al. Awareness of disability in patients following stroke. Rehabil Psychol. 1992;37:103-19.
Hibbard MR, Gordon WA, Stein P, Grober S, Sliwinski M. A multimodal approach to the diagnosis of post stroke depression In: Gordon WA, editor. Advances in stroke rehabilitation, Boston: Andover Publishers;1993
Hier DB, Edelstein G. Deriving clinical prediction rules from stroke outcome research Stroke 1991 Nov 22(11):1431 6 1750053
Hier DB, Mondlock J, Caplan LR. Behavioral abnormalities after right hemisphere stroke Neurology 1983 Mar 33(3):337 44 6681879
Hocherman S, Dickstein R, Pillar T. Platform training and postural stability in hemiplegia Arch Phys Med Rehabil 1984 Oct 65(10):588 92 6487062
Holbrook M, Skilbeck CE. An activities index for use with stroke patients Age Ageing 1983 May 12(2):166 70 6869117
Holland A. Pragmatic aspects of intervention in aphasia. J Neurolinguistics. 1991;6:197-211.
Holland AL. The usefulness of treatment for aphasia: a serendipitous study In: Brookshire RH, editor. Proceedings of the conference on clinical aphasiology, Minneapolis: BRK Publishers;1980 p. 240 7
Horner J, Massey EW. Silent aspiration following stroke Neurology 1988 Feb 38(2):317 9 3340301
Horner J, Massey EW, Riski JE, Lathrop DL, Chase KN. Aspiration following stroke: clinical correlates and outcome Neurology 1988 Sep 38(9):1359 62 3412582
House A, Dennis M, Hawton K, Warlow C. Methods of identifying mood disorders in stroke patients: experience in the Oxfordshire community stroke project Age Ageing 1989 Nov 18(6):371 9 2629484
House A, Dennis M, Morgridge L, Warlow C, Hawton K, Jones L. Mood disorders in the year after first stroke. Br J Psychiatry. 1991;158:83-92. [pmid: 2015456].
House A, Dennis M, Warlow C, Hawton K, Molyneux A. The relationship between intellectual impairment and mood disorder in the first year after stroke. Psychol Med. 1990;20:805-14. [pmid: 2284389].
Hurd WW, Pegram V, Nepomuceno C. Comparison of actual and simulated EMG biofeedback in the treatment of hemiplegic patients Am J Phys Med 1980 Apr 59(2):73 82 7377291
Hyams DE. Psychological factors in rehabilitation of the elderly. Gerontol Clin. 1969;11:129-36.
Inaba M, Edberg E, Montgomery J, Gillis MK. Effectiveness of functional training, active exercise, and resistive exercise for patients with hemiplegia Phys Ther 1973 Jan 53(1):28 35 4682697
Indredavik B, Bakke F, Solberg R, Rokseth R, Haaheim LL, Holme I. Benefit of a stroke unit: a randomized controlled trial Stroke 1991 Aug 22(8):1026 31 1866749
Inglis J, Donald MW, Monga TN, Sproule M, Young MJ. Electromyographic biofeedback and physical therapy of the hemiplegic upper limb Arch Phys Med Rehabil 1984 Dec 65(12):755 9 6391417
Jette AM, Branch LG. The Framingham disability study: II. Physical disability among the aging. Am J Public Health. 1981;71:1211-16. [pmid: 7294262]. [pmcid: 1619934].
Jimenez J, Morgan PP. Predicting improvement in stroke patients referred for inpatient rehabilitation Can Med Assoc J 1979 Dec 8 121(11):1481 4 519575
John J. Failure of electrical myofeedback to augment the effects of physiotherapy in stroke Int J Rehabil Res 1986 9(1):35 45 3488280
Johnston K, Olson E. Application of Bobath principles for nursing care of the hemiplegic patient ARN J 1980 Mar-Apr 5(2):8 11 6901479
Jonas S. Anticoagulant therapy in cerebrovascular disease: review and meta analysis. Stroke. 1988;19:1043-8. [pmid: 3041650].
Jongbloed L. Prediction of function after stroke: a critical review Stroke 1986 Jul-Aug 17(4):765 76 3526649
Jongbloed L, Morgan D. An investigation of involvement in leisure activities after a stroke Am J Occup Ther 1991 May 45(5):420 7 2048623
Jongbloed L, Stacey S, Brighton C. Stroke rehabilitation: sensorimotor integrative treatment versus functional treatment Am J Occup Ther 1989 Jun 43(6):391 7 2741997
Joslin B, Coyne A, Johson T, et al. Dementia and elder abuse: are caregivers victims or villains?. Annual Sci Meeting Gerontol Soc of America. 1991.
Judge JO, Lindsey C, Underwood M, Winsemius D. Balance improvements in older women: effects of exercise training. Physical Ther. 1993;723:254-65.
Kabacoff RI, Miller IW, Bishop DS, Epstein NB, Keitner GI. A psychometric study of the McMaster Family Assessment Device in psychiatric, medical, and nonclinical samples J Fam Psychol 1990 Jun 3(4):431 9
Kalliomaki JL, Markkanen TK, Mustonen VA. Sexual behavior after cerebral vascular accident Fert & Ster 1961 12(2):156 8
Kalra L, Dale P, Crome P. Improving stroke rehabilitation. Stroke. 1993;24:1462-7. [pmid: 8378947].
Kase C, Wolf PA, Kelly-Hayes M, Kannel WB, Bachman DL, Linn RT, D'Agostino RB. Intellectual decline following stroke: the Framingham Study Neurology 1987 Mar 37(Suppl I):
Katrak PH, Cole AMD, Poulos CJ, McCauley JCK. Objective assessment of spasticity, strength, and function with early exhibition of dantrolene sodium after cerebrovascular accident: a randomized double-blind study. Arch Phys Med Rehabil. 1992 Jan;73:4-9. [pmid: 1729971].
Katz S, Ford AB, Moskowitz RW, Jackson BA, Jaffe MW. Studies of illness in the aged: The index of ADL; a standardized measure of biological and psychosocial function. JAMA. 1963 Sep 21:914-9.
Katz RT, Golden RS, Butter J, Tepper D, Rothke S, Holmes J, Sahgal V. Driving safety after brain damage: follow-up of twenty-two patients with matched controls. Arch Phys Med Rehabil. 1990 Feb;71:133-7. [pmid: 2302047].
Kaufman KL, Tarnowski KJ, Simonian SJ, Graves K. Assessing the readability of family assessment self-report measures Psych Assess: J Consult & Clin Psychol 1991 3(4):697 700
Keith RA, Granger CV, Hamilton BB, Sherwin FS. The functional independence measure: a new tool for rehabilitation In: Eisenberg MG, Grzesiak RC, editors. Advances in clinical rehabilitation. Volume 1, New York: Springer-Verlag;1987 p. 6 18
Kelly-Hayes M, Jette AM, Wolf PA, D'Agostino RB, Odell PM. Functional limitations and disability among elders in the Framingham Study. Am J Public Health. 1992 Jun;82:841-5. [pmid: 1533995]. [pmcid: 1694176].
Kelly-Hayes M, Wolf PA, Kannel WB, Sytkowski P, D'Agostino RB, Gresham GE. Factors influencing survival and need for institutionalization following stroke: : the Framingham Study Arch Phys Med Rehabil 1988 Jun 69(6):415 8 3377666
Kelly-Hayes M, Wolf PA, Kase CS, Gresham GE, Kannel WB, D'Agostino RB. Time course of functional recovery after stroke: the Framingham Study J Neurol Rehabil 1989 3(2):65 70
Kertesz A. Western Aphasia Battery, New York: Grune & Stratton;1982
Kiernan RJ. The Neurobehavioral Cognitive Status Examination Northern California Neuro Group;1987
Kiernan RJ, Mueller J, Langston JW, Van Dyke C. The Neurobehavioral Cognitive Status Examination: a brief but differentiated approach to cognitive assessment Ann Intern Med 1987 107 481 5 or 3631786
Kinsella G, Ford B. Acute recovery patterns in stroke patients: neuropsychological factors Med J Aust 1980 Dec 13 2(12):663 6 7219301
Kiyohara Y, Ueda K, Hasuo Y, Wada J, Kawano H, Kato I, Sinkawa A, Ohmura T, Iwamoto H, Omae T, Fujishima M. Incidence and prognosis of subarachnoid hemorrhage in a Japanese rural community. Stroke. 1989;20:1150-5. [pmid: 2772975].
Kojima S, Omura T, Wakamatsu W, Kishi M, Yamazaki T, Iida M, Komachi Y. Prognosis and disability of stroke patients after 5 years in Akita, Japan. Stroke. 1990;21:72-7. [pmid: 2300993].
Korner E, Flooh E, Reinhart B, Wolf R, Ott E, Krenn W, Lechner H. Sleep alteration in ischemic stroke Eur Neurol 1986 25(2):104 10 3758112
Kotila M, Waltimo O, Niemi ML, Loaksoner R, Lempinen M. The profile of recovery from stroke and factors influencing outcome Stroke 1984 Nov-Dec 15(6):1039 44 6506115
Kraft GH, Fitts SS, Hammond MC. Techniques to improve function of the arm and hand in chronic hemiplegia Arch Phys Med Rehabil 1992 Mar 73(3):220 7 1543423
Kramer M, German P, Anthony J, et al. Patterns of mental disorders among elderly residents of Eastern Baltimore. J Am Geriatr Soc. 1985;33:236-45. [pmid: 3989184].
Krefting L, Krefting D. Leisure activities after a stroke: an ethnographic approach Am J Occup Ther 1991 May 45(5):429 36 2048624
Kumar R, Metter EJ, Mehta AJ, Chew T. Shoulder pain in hemiplegia: The role of exercise Am J Phys Med Rehabil 1990 Aug 69(4):205 8 2383382
Landi G, D'Angelo A, Boccardi E, Candelise L, Mannucci PM, Morabito A, Orazio EN. Venous thromboembolism in acute stroke: Prognostic importance of hypercoagulability. Arch Neurol. 1992;49:279-83. [pmid: 1536631].
Langhorne P, Williams BO, Gilchrist W, Howie K. Do stroke units save lives?. Lancet. 1993 Aug;342:395-8. [pmid: 8101901].
Laupacis A, Albers G, Dunn M, Feinberg WM. Antithrombotic therapy in atrial fibrillation. Chest. 1992;102:4265-335.
Lawton MP. Assessing the competence of older people In: Kent D, Kastenbaum R, Sherwood S, editors. Research planning and action for the elderly, New York: Behavioral Publications;1972
Lawton MP. Instrumental Activities of Daily Living (IADL) Scale: original observer-rated version Psychopharmacol Bull 1988a 24(4):785 7 3249785
Lawton MP. Instrumental Activities of Daily Living (IADL) Scale: self-rated version Psychopharmacol Bull 1988b 24(4):789 91 3249786
Legh-Smith J, Wade DT, Hewer RL. Driving after a stroke J R Soc Med 1986 Apr 79(4):200 3 3701764 1290273
Lehmann JF, DeLateur BJ, Fowler RS Jr, Warren CG, Arnhold R, Schertzer G, Hurka R, Whitmore JJ, Masock AJ, Chambers KH. Stroke: Does rehabilitation affect outcome? Arch Phys Med Rehabil 1975 Sep 56(9):375 82 809022
Levin MF, Hui-Chan CW. Relief of hemiparetic spasticity by TENS is associated with improvement in reflex and voluntary motor functions Electroencephalogr Clin Neurophysiol 1992 Apr 85(2):131 42 1373366
Levine DN. Unawareness of visual and sensorimotor defects: hypothesis. Brain Cognition. 1990;13.
Levy DE, Bates D, Caronna JJ, et al. Prognosis in non-traumatic coma. Ann Intern Med. 1981;94:293-301. [pmid: 7224376].
Lichtenberg P, Barth J. Depression in elderly caregivers: a longitudinal study to test Lewinshen's model of depression. Med Psychother. 1990;3:147-56.
Lichtenberg P, Christensen B, Metler L. The role of cognition and depression in functional recovery during geriatric rehabilitation. J Clin Exper Neuropsychotherapy. 1993;15.
Lichtenberg PA, Gibbons TA. Geriatric rehabilitation and the older adult family caregiver Neurorehabilitation 1992 3(1):62 71
Lincoln NB, McGuirk E, Mulley GP, Lendrem W, Jones AC, Mitchell JR. Effectiveness of speech therapy for aphasic stroke patients: A randomised controlled trial Lancet 1984 Jun 2 1(8388):1197 200 6202993
Linden P, Siebens AA. Dysphagia: predicting laryngeal penetration Arch Phys Med Rehabil 1983 Jun 64(6):281 4 6860100
Lipkin DP, Scriven AJ, Crake T, Poole-Wilson PA. Six minute walking test for assessing exercise capacity in chronic heart failure. BMJ. 1986;292:653-5. [pmid: 3081210]. [pmcid: 1339640].
Lipsey JR, Robinson RG, Pearlson GD, Rao K, Price TR. Nortriptyline treatment of post-stroke depression: a double-blind study Lancet 1984 Feb 11 1(8372):297 300 6141377
Loewen SC, Anderson BA. Reliability of the modified Motor Assessment Scale and the Barthel index. Physical Therapy. 1988;68:1077-81. [pmid: 3387463].
Logemann JA. A manual for the videofluoroscopic evaluation of swallowing, San Diego, CA: College Hill;1986
Logigian MK, Samuels MA, Falconer J, Zagar R. Clinical exercise trial for stroke patients Arch Phys Med Rehabil 1983 Aug 64(8):364 7 6882175
Lord JP, Hall K. Neuromuscular reeducation versus traditional programs for stroke rehabilitation Arch Phys Med Rehabil 1986 Feb 67(2):88 91 3954571
Lord SR, Clark RD, Webster IW. Postural stability and associated physiological factors in a population of aged persons J Gerontol 1991 May 46(3): M69 76 2030269
Louis Harris and Associates. The ICD survey of disabled Americans: bringing disabled Americans into the mainstream; A nationwide survey of 1,000 disabled people. Conducted for ICD-International Center for the Disabled, New York, New York, in cooperation with the National Council on the Handicapped, Washington, DC. 1986.
Lovett S, Gallager D. Psychoeducational interventions for family caregivers. Behav Ther. 1988;19:321-30.
Lundgren-Lindquist B, Aniansson A, Rundgren A. Functional studies in 79 year olds: walking performance and climbing capacity. Scand J Rehabil Med. 1983;15:125-31. [pmid: 6635602].
MacKenzie CR, Charlson ME, Digioia D, DiGioia D, et al. Can the Sickness Impact Profile measure change?: An example of scale assessment. J Chronic Dis. 1986;39:429-38. [pmid: 3711251].
MacNeil RD, Pringnitz TD. The role of therapeutic recreation in stroke rehabilitation. Ther Rec J. 1982;Qu. 4:26-34.
Mahoney FI, Barthel DW. Functional evaluation: the Barthel Index. Maryland State Med J. 1965;14:61-5.
Mandel AR, Nymark JR, Balmer SJ, Grinnell DM, O'Riain MD. Electromyographic versus rhythmic positional biofeedback in computerized gait retraining with stroke patients Arch Phys Med Rehabil 1990 Aug 71(9):649 54 2375668
Marsh EE III, Adams HP Jr, Biller J, Wasek P, Banwart K, Mitchell V, Woolson R. Use of antithrombotic drugs in the treatment of acute ischemic stroke: a survey of neurologists in practice in the United States. Neurology. 1989;39:1631-4. [pmid: 2586780].
Marshall RS, Mohr JP. Current management of ischaemic stroke. J Neurol Neurosurg Psychiatry. 1993;56:6-16. [pmid: 8429324]. [pmcid: 1014757].
Matchar DB, McCrory DC, Barnett HJM, Feussner JR. Medical treatment for stroke prevention Ann Intern Med 1994 Jul 1 121(1):41 53 7880225
Matsumoto. Stroke. 1973;73;4:20-9. [pmid: 4685804].
Mayberg MR, Wilson SE, Yatsu F, et al. Carotid endarterectomy and prevention of cerebral ischaemia in symptomatic carotid stenosis. JAMA. 1991;266:3289-94. [pmid: 1960828].
Maynard FM, Diokno AC. Urinary infection and complications during clean intermittent catheterization following spinal cord injury J Urol 1984 132(5):943 6 6333518
McCormick GP, Riffer DJ, Thompson MM. Coital positioning for stroke afflicted couples Rehabil Nurs 1986 Mar-Apr 11(2):17 9 3635152
McCormick KA, Scheve AAS, Leahy E. Nursing management of urinary incontinence in geriatric inpatients Nurs Clin North Am 1988 23(1):231 64 3347579
McFarlane AH, Norman GR, Streiner DL, Roy RG. The process of social stress: stable, reciprocal and mediating relationships J Health Soc Behav 1983 24(2):160 73 6886370
McGovern PG, Burke GL, Sprafke JM, Xue S, Folsom AR, Blackburn H. Trends in mortality, morbidity, and risk factor levels for stroke from 1960 through 1990. The Minnesota Heart Survey JAMA 1992 92Aug2 268(6):753 9 1640576
McHorney CA, Ware JE, Rogers W, et al. The validity and relative precision of MOS short- and long-form health status scales and Dartmouth COOP charts: results from the Medical Outcomes Study Med Care 1992 30(5 Suppl): MS253 65 1583937
Meerwaldt JD. Spatial disorientation in right-hemisphere infarction: a study of the speed of recovery. J Neurol Neurosurg Psychiatry. 1983;46:426-9. [pmid: 6101178]. [pmcid: 1027391].
Merletti R, Zelaschi F, Latella D, Galli M, Angeli S, Sessa MB. A control study of muscle force recovery in hemiparetic patients during treatment with functional electrical stimulation Scand J Rehabil Med 1978 10(3):147 54 705282
Miller IW, Bishop DS, Epstein NB, Keitner GI. The McMaster Family assessment device: reliability and validity J Marital and Fam Ther 1985 Oct 11(4):345 56
Mion L, Gregor S, Chwirchak D, Paras W. Falls in the rehabilitation setting: incidence and characteristics Rehabil Nurs 1989 14(1):17 22 2911696
Mitchum CC, Handiges A, Berndt R. Model-guided treatment to improve written sentence production: a case study. Aphasiology. 1993;7:71-110.
Mol VJ, Baker CA. Activity intolerance in the geriatric stroke patient Rehabil Nurs 1991 Nov-Dec 16(6):337 43 1957055
Monga TN, Lawson JS, Inglis J. Sexual dysfunction in stroke patients Arch Phys Med Rehabil 1986 Jan 67(1):19 22 3942478
Morris PLP, Robinson RG, Andrzejewski P, Samuels J, Price TR. Association of depression with 10-year poststroke mortality. Am J Psychiatry. 1993;150:124-9. [pmid: 8417554].
Morris PL, Robinson RG, Raphael B. Prevalence and course of post-stroke depression [depressive disorders] in hospitalized [stroke] patients. Int J Psychiatry Med. 1990;20:327-42.
Mulder T, Hulstijn W, van der Meer J. EMG feedback and the restoration of motor control: A controlled group study of 12 hemiparetic patients Am J Phys Med 1986 Aug 65(4):173 88 3526915
Mysiw WJ, Beegan JG, Gatens PF. Prospective cognitive assessment of stroke patients before inpatient rehabilitation: The relationship of the Neurobehavioral Cognitive Status Examination to functional improvement Am J Phys Med Rehabil 1989 Aug 68(4):168 71 2765207
Nadolsky J. An experimental trend in assessment. In: Smith C, Fry R, editors. National forum on issues in vocational assessment: the issue papers. Menomonie (WI): University of Wisconsin-Stout, Stout Vocational Rehabilitation Institute, Materials Development Center. 1985.
Nagi S. Disability concepts revisited: implications for prevention In: Sussman MG, editor. Sociology and rehabilitation, Washington, DC: American Sociological Association;1965 p. 100 13
National Institute of Neurological Disorders and Stroke. Clinical advisory: carotid endarterectomy for patients with asymptomatic internal carotid artery stenosis National Institutes of Health; Sep 28 1994
National Association of Rehabilitation Facilities. Medical rehabilitation: what it is and where is it?, Washington, DC; November 1988
National Stroke Association Consensus Statement. Stroke: the first six hours, emergency evaluation and treatment In: McDowell FH, editor. Stroke: clinical updates 1993 2(1).
Niemi ML, Laaksonen R, Kotila M, Waltimo O. Quality of life 4 years after stroke Stroke 1988 Sep 19(9):1101 7 3413807
Norris JT, Gallager D, Wilson A, Winograd CH. Assessment of depression in geriatric medical outpatients: the validity of two screening measures. J Am Geriatr Soc. 1987;35:989-95. [pmid: 3668142].
North American Symptomatic Carotid Endarterectomy Trial Collaborators. Beneficial effect of carotid endarterectomy in symptomatic patients with high-grade stenosis. N Engl J Med. 1991;325:445-53. [pmid: 1852179].
Norton D, McLaren R, Exton-Smith AN. An investigation of geriatric nursing problems in the hospital, London: National Corporation for the Care of Old People;1962
Nouri FM, Tinson DJ, Lincoln NB. Cognitive ability and driving after stroke. International Disability Studies. 1987;9:110-5. [pmid: 3429395].
Osmon DC, Smet IC, Winegarden B, Gandhavadi B. Neurobehavioral Cognitive Status Examination: its use with unilateral stroke patients in a rehabilitation setting. Arch Phys Med Rehabil. 1992;73:V:414-8. [pmid: 1580766].
Oxfordshire Community Stroke Project. Incidence of stroke in Oxfordshire: first year's experience of a community stroke register. BMJ. 1983;287:713-17. [pmid: 6412794]. [pmcid: 1549038].
Pain HSB, McLellan DL. The use of individualized booklets after stroke. Clin Rehabil. 1990;4:265-72.
Palmer JB, DeChase AS. Rehabilitation of swallowing due to strokes. Phys Med Rehab Clin N Amer. 1991;2:529-46.
Panel for the Prediction and Prevention of Pressure Ulcers in Adults 1992. Pressure ulcers in adults; prediction and prevention Clinical practice guideline no. 3 (AHCPR publication no. 92-0047), Rockville (MD): Agency for Health Care Policy and Research.
Parikh RM, Eden DT, Price TR, Robinson RG. The sensitivity and specificity of the Center for Epidemiologic Studies Depression Scale in screening for post-stroke depression Int J Psychiatry Med 1988 18(2):169 81 3170080
Parikh RM, Robinson RG, Lipsey JR, Starkstein SE, Federoff JP, Price TE. The impact of post-stroke depression on recovery in activities of daily living over a two-year follow-up. Arch Neurol. 1990;47:785-9. [pmid: 2357159].
Peterson P, Boysen G, Godtfredsen J, Andersen ED, Andersen B. Placebo-controlled, randomized trial of warfarin and aspirin for prevention of thromboembolic complications in chronic atrial fibrillation. Lancet. 1989;1:175-8. [pmid: 2563096].
Phipps M. Total patient care: foundations and practice of adult health nursing rehabilitation In: Harkness GG, Dincher J, editors, St. Louis (MO): Mosby Year Books;1990
Pizzamiglio L, Frasca R, Guariglia C, Incoccia C, Antonucci G. Effect of optokinetic stimulation in patients with visual neglect. Cortex. 1990;26:535-40. [pmid: 2081391].
Poeck K, Huber W, Willmes K. Outcome of intensive language treatment in aphasia. J Speech Hear Disord. 1989 Aug;54:471-9. [pmid: 2755107].
Poole JL, Whitney SL, Hangeland N, Baker C. The effectiveness of inflatable pressure splints on motor function in stroke patients Occup Ther J Res 1990 Nov-Dec 10(6):360 6
Poole JL, Whitney SL. Motor assessment scale for stroke patients: concurrent validity and interrater reliability Arch Phys Med Rehabil 1988 Mar 69(3 Pt 1):195 7 3348720
Poplingher AR, Pillar T. Hip fracture in stroke patients: Epidemiology and rehabilitation Acta Orthop Scand 1985 Jun 56(3):226 7 4036571
Porch B. Porch Index of Communicative Ability (PICA), Palo Alto, CA: Consulting Psychologists Press;1981
Portnow J, Kline T, Daly M, Peltier SM, Chin C, Miller JR. Multidisciplinary home rehabilitation: a practical model Clinics in Geriatric Medicine 1991 Nov 7(4):695 706 1760789
Prescott Survey shows stroke to be one of the most expensive medical illnesses in the United States Internal Medicine World Report 1994 June 15 9(12):1 5
Radloff LS. The CES-D scale: a self-report depression scale for research in the general population. J Appl Psychol Meas. 1977;1:385-401.
Rankin J. Cerebral vascular accidents in patients over the age of 60. Scott Med J. 1957;2:200-15. [pmid: 13432835].
Rapport LJ, Webster JS, Fleming KL, Lindberg JW, Godlewski MC, Brhee JE, Abadee PS. Predictors of falls among right hemisphere stroke patients in the rehabilitation setting. Arch Phys Med Rehabil. 1993;74:621-6. [pmid: 8503752].
Reding MJ, Orto LA, Winter SW, Fortuna IM, Di Ponte P, McDowell FH. Antidepressant therapy after stroke: a double-blind trial Arch Neurol 1986 Aug 43(8):763 5 3729755
Reding MJ, Winter SW, Hochrein SA, Simon HB, Thompson MM. Urinary incontinence after unilateral hemispheric stroke: a neurologic-epidemiologic perspective. J Neuro Rehabil. 1987;1:25-30.
Robertson IH, Gray JM, Pentland B, Waite LJ. Microcomputer-based rehabilitation for unilateral left visual neglect: a randomized controlled trial Arch Phys Med Rehabil 1990 Aug 71(9):663 8 2375671
Robinson RG, Benson DF. Depression in aphasic patients: frequency, severity, and clinical- pathological correlations Brain Lang 1981 Nov 14(2):282 91 7306784
Robinson R, Bolduc GA, Kubos KL. Social functioning assessment in stroke patients. Arch Phys Med Rehabil. 1985;66:496-500. [pmid: 4026549].
Robinson RG, Bolduc PL, Price TR. A two-year longitudinal study of post-stroke mood disorders: diagnosis and outcome at one and two years Stroke 1987 Sep-Oct 18(5):837 43 3629640
Robinson RG, Parikh RM, Lipsey JR, Starkstein SE, Price TR. Pathological laughing and crying following stroke: validation of a measurement scale and a double-blind study. Am J Psychiatry. 1993;150:286-93. [pmid: 8422080].
Robinson RG, Price TR. Post-stroke depressive disorders: a follow-up study of 103 patients Stroke 1982 Sep-Oct 13(5):635 41 7123596
Robinson RG, Starr LB, Kubos KL, Price TR. A two-year longitudinal study of post-stroke mood disorders: findings during the initial evaluation Stroke 1983 Sep-Oct 14(5):736 44 6658957
Robinson RG, Starr LB, Lipsey JR, Rao K, Price TR. A two-year longitudinal study of poststroke mood disorders: In-hospital prognostic factors associated with six-month outcome J Nerv Ment Dis 1985 Apr 173(4):221 6 3981156
Robinson RG, Szetela B. Mood change following left hemispheric brain injury. Ann Neurol. 1981;9:447-53. [pmid: 7271239].
Rosenbek D. The dysarthrias In: Johns D, editor. Clinical management of neurogenic communicative disorders, Boston: Little Brown;1985
Rosow I, Breslau N. A Guttman health scale for the aged. J Gerontol. 1966;21:556-9. [pmid: 5918309].
Rossi PW, Kheyfets S, Reding MJ. Fresnel prisms improve visual perception in stroke patients with homonymous hemianopsia or unilateral visual neglect Neurology 1990 Oct 40(10):1597 9 2215953
Roth EJ. The elderly stroke patient: principles and practices of rehabilitation management Top Geriatr Rehabil 1988 3(4):27 61
Roth EJ. Medical complications encountered in stroke rehabilitation Phys Med Rehabil Clin N Amer 1991 Aug 2(3):563 78
Roth EJ, Mueller K, Green D. Stroke rehabilitation outcome: impact of coronary artery disease Stroke 1988 Jan 19(1):42 7 3336900
Rothberg J. The rehabilitation team: future direction. Arch Phys Med Rehabil. 1981;62:407-11. [pmid: 7259477].
Roy C. Shoulder pains in hemiplegia: a literature review. Clin Rehabil. 1988;2:35-44.
Rubens AB. Caloric stimulation and unilateral visual neglect. Neurology. 1985;35:1019-24. [pmid: 4010940].
Rubenstein LZ, Robbins AS, Josephson KR, Schulman BL, Osterweil D. The value of assessing falls in an elderly population: a randomized clinical trial. Ann Int Med. 1990;131:308-16. [pmid: 2115755].
Rubenstein LZ, Schairer C, Wieland GD, Kane R. Systematic biases in functional status assessment of elderly adults: effects of different data sources J Gerontol 1984 Nov 39(6):686 91 6436360
Sabanthan K, Sabanathan K, Castleden CM, Mitchell CJ. The problem of bacteriuria with indwelling urethral catheterization Age Ageing 1985 14(2):85 90 4003188
Sacco RL, Wolf PA, Kannel WB, McNamara PM. Survival and recurrence following stroke: The Framingham Study Stroke 1982 May-Jun 13(3):290 5 7080120
Sandercock P, Willems H. Medical treatment of acute ischemic stroke. Lancet. 1992;339:537-9. [pmid: 1346888].
Sarno MT. Functional Communication Profile (FCP) New York University Medical Center Monograph Department, New York: New York University;1969
Schenkenberg T, Bradford DC, Ajax ET. Line bisection and unilateral visual neglect in patients with neurologic impairment. Neurology. 1980;30:509-17. [pmid: 7189256].
Schleenbaker RE, Mainous III AG. Electromyographic biofeedback for neuromuscular reeducation in the hemiplegic stroke patient: : a meta-analysis. Arch Phys Med Rehabil. 1993 Dec;74:1301-4. [pmid: 8259896].
Schnelle JF. Treatment of urinary incontinence in nursing home patients by prompted voiding J Am Geriatr Soc 1990 38(3):356 60 2313014
Schoening HA, Iversen IA. Numerical scoring of self-care status: a study of the Kenny self-care evaluation Arch Phys Med Rehabil 1968 Apr 49(4):221 9 5647959
Schubert DS, Burns R, Paras W, Sioson E. Decrease of depression during stroke and amputation rehabilitation Gen Hosp Psychiatry 1992a Mar 14(2):135 41 1592250
Schubert DS, Burns R, Paras W, Sioson E. Increase of medical hospital length of stay by depression in stroke and amputation patients: a pilot study Psychother Psychosom 1992b 57(1-2):61 6 1584900
Schubert DS, Taylor C, Lee S, Mentari A, Tamaklo W. Detection of depression in the stroke patient Psychosomatics 1992c Summer 33(3):290 4 1410202
Schubert DS, Taylor C, Lee S, Mentari A, Tamaklo W. Physical consequences of depression in the stroke patient Gen Hosp Psychiatry 1992d Jan 14(1):69 76 1730403
Schuling J, de Haan R, Limburg M, Groenier KH. The Frenchay Activities Index: assessment of functional status in stroke patients Stroke 1993 Aug 24(8):1173 7 8342192
Schultz R, Uisintainer P, Schulz R, Visintainer P, Williamson G. Psychiatric and physical morbidity effects of caregiving. J Gerontol Psych Sci. 1990;45:181-91.
Schwamm LH, Van Dyke C, Keirnana RS, Merrin EL, Mueller J. The Neurobehavioral Cognitive Status Examination: comparison with the Cognitive Capacity Screening Examination and the Mini-Mental State Examination in a neurosurgical population. Ann Intern Med. 1987;107:486-91. [pmid: 3631787].
Sedrat SM, Hecht JS. Urologic problems after stroke (part II) Stroke Clinical Updates 1993 4(Pt 2):21 4
Shah S, Vanclay F, Cooper B. Improving the sensitivity of the Barthel Index for stroke rehabilitation J Clin Epidemiol 1989 42(8):703 9 2760661
Shank J(The National Center for Medical Rehabilitation Research).The role of therapeutic recreation in rehabilitation research 1992 Mar 6
Shewan C, Bandur D. Treatment of aphasia: a language-oriented approach, San Diego, CA: College Hill;1982
Shewan CM, Kertesz A. Effects of speech and language treatment on recovery from aphasia Brain Lang 1984 Nov;23(2):272 99 6083819
Shiavi RG, Champion SA, Freeman FR, Bugel HJ. Efficacy of myofeedback therapy in regaining control of lower extremity musculature following stroke Am J Phys Med 1979 Aug 58(4):185 94 464030
Shinar D, Gross CR, Bronstein KS, et al. Reliability of the Activities of Daily Living Scale and its use in telephone interviews. Arch Phys Med Rehabil. 1987;68:723-8. [pmid: 3662782].
Shinar D, Gross CR, Price TR, Banko M, Bolduc PL, Robinson RG. Screening for depression in stroke patients: the reliability and validity of the Center for Epidemiologic Studies Depression Scale Stroke 1986 Mar-Apr 17(2):241 5 3961834
Shinton R, Beevers G. Meta-analysis of relation between cigarette smoking and stroke BMJ 1989 Mar 25 298(6676):789 94 2496858
Shumway-Cook A, Anson D, Haller S. Postural sway biofeedback: its effect on reestablishing stance stability in hemiplegic patients Arch Phys Med Rehabil 1988 Jun 69(6):395 400 3377664
Silliman RA, Wagner EH, Fletcher RH. The social and functional consequences of stroke for elderly patients Stroke 1987 Jan-Feb 18(1):200 3 3810753
Silver FL, Norris JW, Lewis AJ, Hachinski VC. Early mortality following stroke: a prospective study. Stroke. 1984;25.
Sivak M, Hill CS, Henson DL, Butler BP, Silber SM. Improved driving performance following perceptual training in persons with brain damage. Arch Phys Med Rehabil. 1984;65:163-7. [pmid: 6712432].
Sivak M, Olsen PL, Kewman DG, Won H, Henson DL. Driving and perceptual/cognitive skills: behavioral consequences of brain damage. Arch Phys Med Rehabil. 1981;62:476-83. [pmid: 7305641].
Sivenius J, Pyorala K, Heinonen OP, Salonen JT, Riekkinen P. The significance of intensity of rehabilitation of stroke: a controlled trial Stroke 1985 Nov-Dec 16(6):928 31 3911506
Sjogren K. Leisure after stroke Int Rehabil Med 1982 4(2):80 7 7174217
Sjogren K, Damber JE, Liliequist B. Sexuality after stroke with hemiplegia: I. Scand J Rehabil Med. 1983;15:55-61. [pmid: 6867636].
Sjogren K, Fugl-Meyer AR. Adjustment to life after stroke with special reference to sexual intercourse and leisure J Psychosom Res 1982 26(4):409 17 7143281
Skilbeck CE, Wade DT, Hewer RL, Wood VA. Recovery after stroke J Neurol Neurosurg Psychiatry 1983 Jan 46(1):5 8 6842200 1027255
Smith DS, Goldenberg E, Ashburn A, Kinsella G, Sheikh K, Brennan PJ, Meade TW, Zutshi DW, Perry JD, Reeback JS. Remedial therapy after stroke: a randomised controlled trial BMJ (Clin Res) 1981 Feb 14 282(6263):517 20
Smith ME, Garraway WM, Smith DL, Akhtar AJ. Therapy impact on functional outcome in a controlled trial of stroke rehabilitation Arch Phys Med Rehabil 1982 Jan 63(1):21 4 7034669
Smolkin C, Cohen BS. Socioeconomic factors affecting the vocational success of stroke patients. Arch Phys Med Rehabil. 1974 Jun;55:269-71. [pmid: 4841633].
Soderback I. The effectiveness of training intellectual functions in adults with acquired brain damage: an evaluation of occupational therapy methods Scand J Rehabil Med 1988 20(2):47 56 3406681
Springer L, Glindemann R, Huber W, Willmes K. How efficacious is PACE therapy when language systematic training is incorporated?. Aphasiology. 1991;5:391-9.
Starkstein SE, Robinson RG. Neuropsychiatric aspects of stroke In: Coffey CE, Cummings JL, editors. Textbook of geriatric neuropsychiatry, Washington, DC: American Psychiatric Press, Inc.;1994 p. 457 78
Stephens M, Kinney J, Igrocki P. Stressors and well being among caregivers to older adults with dementia: the in-home versus nursing home experience. Gerontol. 1991;31:217-23.
Stern PH, McDowell F, Miller JM, Robinson M. Effects of facilitation exercise techniques in stroke rehabilitation Arch Phys Med Rehabil 1970 Sep 51(9):526 31 5475721
Stevens RS, Ambler NR, Warren MD. A randomized controlled trial of a stroke rehabilitation ward Age Ageing 1984 Mar 13(2):65 75 6731167
Stineman MG, Granger CV. Epidemiology of stroke-related disability and rehabilitation outcome Phys Med Rehabil Clin N Amer 1991 Aug 2(3):457 71
Stone SP, Wilson B, Wroot A, Halligan PW, Lange LS, Marshall JC, Greenwood RJ. The assessment of visuo-spatial neglect after acute stroke J Neurol Neurosurg Psychiatry 1991 Apr 54(4):345 50 2056321 488491
Strand T, Asplund K, Eriksson S, Hagg E, Lithner F, Wester PO. A non-intensive stroke unit reduces functional disability and the need for long-term hospitalization Stroke 1985 Jan-Feb 16(1):29 34 3917584
Stroke prevention in atrial fibrillation (SPAF) investigators. Stroke prevention in atrial fibrillation study final results. Circulation. 1991;84:527-39. [pmid: 1860198].
Studenski S. Falls 2nd ed. Calkins E, editor. The practice of geriatrics, Philadelphia: WB Saunders;1992
Studenski S, Duncan P, Chandler J. Postural responses and effector factors in persons with unexplained falls: results and methodologic issues. J Am Geriatr Soc. 1991;39:229-34. [pmid: 2005334].
Sunderland A, Tinson DJ, Bradley EL, Fletcher D, Langton-Hewer R, Wade DT. Enhanced physical therapy improves recovery of arm function after stroke: A randomised controlled trial J Neurol Neurosurg Psychiatry 1992 Jul 55(7):530 5 1640226 489160
Sunderland A, Tinson DJ, Bradley EL, Fletcher D, Langton-Hewer R, Wade DT. Enhanced physical therapy for arm function after stroke: a one year follow-up study. J Neurol Neurosurg Psychiatry. 1994;57:856-8. [pmid: 8021679]. [pmcid: 1073035].
Susset V, Vobecky J, Black R. Disability outcome and self-assessment of disabled persons: an analysis of 506 cases. Arch Phys Med Rehabil. 1979;60:50-6. [pmid: 157111].
Takebe K, Kukulka CG, Narayan MG, Basmajian JV. Biofeedback treatment of foot drop after stroke compared with standard rehabilitation technique (Pt 2): effects on nerve conduction velocity and spasticity Arch Phys Med Rehabil 1976 Jan 57(1):9 11 1247378
Tangeman PT, Banaitis DA, Williams AK. Rehabilitation of chronic stroke patients: changes in functional performance Arch Phys Med Rehabil 1990 Oct 71(11):876 80 2222155
Tatemichi TK, Desmond DW, Paik M. Mini-Mental Status Exam as a screen for dementia after stroke. J Clin Exper Psych. 1991;13.
Taub E, Miller NE, Novack TA, Cook EW, Fleming WC, Nepmuceno CS, Connell JS, Crago JE. Technique to improve chronic motor deficit after stroke. Arch Phys Med Rehabil. 1993 April;74:347-54. [pmid: 8466415].
Taylor MM, Schaeffer JN, Blumenthal FS, Grisell JL. Perceptual training in patients with left hemiplegia Arch Phys Med Rehabil 1971 Apr 52(4):163 9 5574690
Teasdale G, Jennett B. Assessment of coma and impaired consciousness: a practical scale. Lancet. 1974;2:81-3. [pmid: 4136544].
Teasdale G, Knill-Jones R, Van der Sande J. Observer variability in assessing impaired consciousness and coma. J Neurol Neurosurg Psychiatry. 1978;41:603-10. [pmid: 690637]. [pmcid: 493103].
Teasdale G, Murray G, Parker L, Jennett B. Adding up the Glasgow Coma Scale Acta Neurochir 1979 28(Suppl):13 6
Terent A. Stroke morbidity In: Whisnant J, editor. Stroke: populations, cohorts, and clinical trials, Oxford; Boston: Butterworth-Heineman;1993
Therapeutics and Technology Assessment Subcommittee of the American Academy of Neurology. Assessment: melodic intonation therapy. Neurology. 1994;44:566-8. [pmid: 8145935].
Thomas DF. Vocational Assessment Protocol (VAP) University of Wisconsin-Stout, Research and Training Center;1990
Tinetti M. Performance oriented assessment of mobility problems in elderly patients. JAGS. 1986;34:119-25.
Tinetti ME, Baker DI, McAvay G, Claus EB, Garrett P, Gottschalk M, Koch ML, Trainor K, Horwitz RI. A multifactorial intervention to reduce the risk of falling among elderly people living in the community N Engl J Med 1994 Sep 29 331(13):821 7 8078528
Tinetti ME, Ginter SF. Identifying mobility dysfunctions in elderly patients: standard neuromuscular examination or direct assessment? JAMA 1988 Feb 26 259(8):1190 3 3339820
Titus MN, Gall NG, Yerxa EJ, Roberson TA, Mack W. Correlation of perceptual performance and activities of daily living in stroke patients Am J Occup Ther 1991 May 45(5):410 8 2048622
Tombaugh TN, McIntyre NJ. The Mini-Mental Status Examination: a comprehensive review. J Am Geriatr Soc. 1992;40:922-35. [pmid: 1512391].
Towle D, Lincoln NB, Mayfield LM. Service provision and functional independence in depressed stroke patients and the effect of social work intervention on these J Neurol Neurosurg Psychiatry 1989 Apr 52(4):519 22 2738596 1032308
Trombly CA, Thayer-Nason L, Bliss G, Girard CA, Lyrist LA, Brexa-Hooson A. The effectiveness of therapy in improving finger extension in stroke patients Am J Occup Ther 1986 Sep 40(9):612 7 3766683
Tucker MA, Davison JG, Ogle SJ. Day hospital rehabilitation-effectiveness and cost in the elderly: a randomised controlled trial. BMJ. 1984;289:1209-12. [pmid: 6437487]. [pmcid: 1443331].
Urinary Incontinence Guideline Panel. Urinary incontinence in adults Clinical practice guideline no. 2 (AHCPR publication no. 92-0038), Rockville (MD): Agency for Health Care Policy and Research;1992
van Swieten JC, Koudstaal PJ, Visser MC, Schouten HJ, van Gijn J. Interobserver agreement for the assessment of handicap in stroke patients Stroke 1988 May 19(5):604 7 3363593
van Zomeren AH, Brouwer WH, Minderhoud JM. Acquired brain damage and driving: a review. Arch Phys Med Rehabil. 1987 Oct;68:697-705. [pmid: 3310958].
Veis SL, Logemann JA. Swallowing disorders in persons with cerebrovascular accident Arch Phys Med Rehabil 1985 Jun 66(6):372 5 4004534
Venn M, Taft L, Carpentier B, Applebaugh G. The influence of timing and suppository use on efficiency and effectiveness of bowel training after stroke Rehabil Nurs 1992 17(3):116 20 1585039
Viitanen M, Fugl-Meyer KS, Bernspang B, Fugl-Meyer AR. Life satisfaction in long-term survivors after stroke. Scand J Rehabil Med. 1988;20:17-24. [pmid: 3413451].
Wade DT.In: Stevens A, Raftery J, editors. Health care needs assessment: The epidemiologically based needs assessment reviews; Volume 1, Oxford: Radcliffe Medical Press Ltd.;1994 p. 111 255
Wade DT. Measurement in neurological rehabilitation, Oxford: Oxford University Press;1992
Wade DT, Collen FM, Robb GF, Warlow CP. Physiotherapy intervention late after stroke and mobility BMJ 1992 Mar 7 304(6827):609 13 1559090
Wade DT, Collin C. The Barthel ADL Index: a standard measure of physical disability? Int Disabil Stud 1988 10(2):64 7 3042746
Wade DT, Legh-Smith J, Hewer RA. Depressed mood after stroke: A community study of its frequency. Br J Psychiatry. 1987 Aug;151:200-5. [pmid: 3690109].
Wade DT, Hewer RL. Functional abilities after stroke: measurement, natural history and prognosis J Neurol Neurosurg Psychiatry 1987a Feb 50(2):177 82 3572432 1031489
Wade DT, Hewer RL. Motor loss and swallowing difficulty after stroke: frequency, recovery, and prognosis Acta Neurol Scand 1987b Jul 76(1):50 4 3630644
Wade DT, Hewer RL, David RM, Enderby PM. Aphasia after stroke: natural history and associated deficits J Neurol Neurosurg Psychiatry 1986 Jan 49(1):11 6 2420939 1028640
Wade DT, Langton-Hewer R, Skilbeck CE, Bainton D, Burns-Cox C. Controlled trial of a home-care service for acute stroke patients Lancet 1985 Feb 9 1(8424):323 6 2857372
Wade DT, Legh-Smith J, Langton-Hewer R. Social activities after stroke: measurement and natural history using Frenchay Activities Index. Int Rehabil Med. 1985;7:176-81. [pmid: 4093249].
Wade DT, Parker V, Langton-Hewer R. Memory disturbance after stroke: frequency and associated losses Int Rehabil Med 1986 8(2):60 4 3804598
Wade DT, Wood VA, Hewer RL. Recovery of cognitive function soon after stroke: a study of visual neglect, attention span and verbal recall J Neurol Neurosurg Psychiatry 1988 Jan 51(1):10 3 3351509 1032707
Ward G, Jamrozik K, Stewart-Wynne E. Incidence and outcome of cerebrovascular disease in Perth, Western Australia. Stroke. 1988;19:1501-6. [pmid: 3201509].
Ware JE, Sherbourne CD. The MOS 36-item short-form health survey (SF-36): I. Conceptual framework and item selection Med Care 1992 Jun 30(6):473 83 1593914
Warlow C, Ogston D, Douglas AS. Deep venous thrombosis of the legs after strokes: Part 2. Natural history BMJ 1976 May 15 1(6019):1181 3 1268615
Warren M. Identification of visual scanning deficits in adults after cerebrovascular accident Am J Occup Ther 1990 May 44(5):391 9 2353712
Warren JW, Tenney JH, Hoopes JM, Muncie HL, Anthony WC. A prospective microbiologic study of bacteriuria in patients with chronic indwelling urethral catheters J Infect Dis 1982 164(6):719 23 6815281
Webb RJ, Lawson AL, Neal DE. Clean intermittent self-catheterization in 172 adults Br J Urol 1990 65(1):20 3 2310927
Webster JS, Rapport LJ, Godlewski MC, Abadee PS. Effect of attentional bias to right space on wheelchair mobility. J Clin Exper Neuropsychol. 1994;16:129-37. [pmid: 8150883].
Weinberg J, Diller L, Gordon WA, Gerstman LJ, Lieberman A, Lakin P, Hodges G, Ezrachi O. Training sensory awareness and spatial organization in people with right brain damage Arch Phys Med Rehabil 1979 Nov 60(11):491 6 508074
Weinberg J, Diller L, Gordon WA, Gerstman LJ, Lieberman A, Lakin P, Hodges G, Ezrachi O. Visual scanning training effect on reading-related tasks in acquired right brain damage Arch Phys Med Rehabil 1977 Nov 58(11):479 86 931586
Weinberg J, Piasetsky E, Diller L, Gordon WA. Treating perceptual organization deficits in nonneglecting RBD stroke patients. J Clin Neuropsychol. 1982;4:59-75. [pmid: 7096587].
Weinrich M, Steele R, Carlson G, Kleczewska M, Wertz R, Baker E. Processing of visual syntax by a globally aphasic patient. Brain Lang. 1989;36:391-405. [pmid: 2706445].
Weissman MM, Sholomskas D, Pottengel M, Prusoff BA, Locke BZ. Assessing depressive symptoms in five psychiatric populations: a validity study. Am J Epidemiol. 1977;106:203-14. [pmid: 900119].
Wenniger WFMdB, Hagemand WJPM, Arrindell WA. Cross-national validity of dimensions of family functioning: first experiences with the Dutch version of the McMaster Family Assessment Device (FAD) Pers Indiv Diff 1993 Jun 14(6):769 81
Wertz RT. Response to treatment in patients with apraxia of speech In: McNeill M, Rosenbek J, Aronson, editors. Apraxia of speech: physiology, acoustics, linguistics, management, San Diego, CA: College- Hill;1984
Wertz RT, Collins MJ, Weiss D, Kurtzke JF, Friden T, Brookshire RH, Pierce J, Holtzapple P, Hubbard DJ, Porch BE, West JA, Davis L, Matovitch V, Morley GK, Resurrection E. Veterans Administration cooperative study on aphasia: a comparison of individual and group treatment. J Speech Hear Res. 1981;24:580-94. [pmid: 6173512].
Wertz RT, Weiss DG, Aten JL, Brookshire RH, Garcia-Bunuel L, Holland AL, Kurtzke JF, LaPointe LL, Milianti FJ, Brannegan R, et al. Comparison of clinic, home, and deferred language treatment for aphasia: A Veterans Administration cooperative study Arch Neurol 1986 Jul 43(7):653 8 3524513
Whipple RH, Wolfson LI, Amerman P. The relationship of knee and ankle weakness to falls in nursing home residents: an isokinetic study. J Am Geriatr Soc. 1987;35:13-20. [pmid: 3794141].
Whisnant JP, Fitzgibbons JP, Kurland LT, Sayre GP. Natural History of stroke in Rochester, Minnesota, 1945 through 1954. Stroke. 1971;2:11-22. [pmid: 5112001].
Williams JBW. A structured interview guide for the Hamilton Depression Rating Scale. Arch Gen Psychiatry. 1988;45:742-6. [pmid: 3395203].
Williams & Wilkins, editors. Guide to clinical preventive services: an assessment of the effectiveness of 169 interventions Report of the U.S. Preventive Services Task Force, Washington, DC.;1989
Wilson B, Cockburn J, Halligan P. Development of a behavioral test of visuospatial neglect Arch Phys Med Rehabil 1987 Feb; 68(2):98 102 3813864
Winchester P, Montgomery J, Bowman B, Hislop H. Effects of feedback stimulation training and cyclical electrical stimulation on knee extension in hemiparetic patients Phys Ther 1983 Jul 63(7):1096 103 6602993
Winstein CJ. Motor learning considerations in stroke rehabilitation In: Duncan DW, Badke MB, editors. Stroke rehabilitation: recovery of motor control, Chicago: Year Book Mode Publishers, Inc.;1987
Winstein CJ, Gardner ER, McNeal DR, Barto PS, Nicholson DE. Standing balance training: effect on balance and locomotion in hemiparetic adults Arch Phys Med Rehabil 1989 Oct 70(10):755 62 2802955
Wityk RJ, Pessin MS, Kaplan RF, Caplan LR. Serial assessment of acute stroke using the NIH stroke scale Stroke 1994 Feb 25(2):362 65 8303746
Wolf PA, Abbott RD, Kannel WB. Atrial fibrillation: a major contributor to stroke in the elderly; the Framingham Study Arch Intern Med 1987 Sep 147(9):1561 4 3632164
Wolf PA, Cobb JL, D'Agostino RB. Epidemiology of stroke In: Barnett HJM, Mohr JP, Stein BM, Yatsu FM, editors. Stroke: pathophysiology, diagnosis and management. 2nd ed, New York: Churchill Livingstone;1992
Wolf PA, D'Agostino RB, Odell P, Belanger AJ, Hodges D, Kannel WB. Alcohol consumption as a risk factor for stroke: the Framingham study. Am Neurol Assoc. 1992.
Wolf PA, D'Agostino RB, O'Neal MA. Secular trends in stroke incidence and mortality: The Framingham Study Stroke 1992 Nov 23(11):1551 5 1440701
Wolf SL, LeCraw DE, Barton LA. Comparison of motor copy and targeted biofeedback training techniques for restitution of upper extremity function among patients with neurological disorders Phys Ther 1989 Sept 69(9):719 35 2772035
Wolf SL, LeCraw DE, Barton LA, Jann BB. Forced use of hemiplegic upper extremities to reverse the effect of learned nonuse among chronic stroke and head-injured patients Exp Neurol 1989 May 104(2):125 32 2707361
Wolfson L, Whipple R, Amerman P, Tobin JN. Gait assessment in the elderly: a gait abnormality rating scale and its relation to falls. J Gerontol. 1990;45:M12-19. [pmid: 2295773].
Woo E, Proulx SM, Greenblatt DJ. Differential side effect profile of triazolam versus flurazepam in elderly patients undergoing rehabilitation therapy J Clin Pharmacol 1991 Feb 31(2):168 73 2010562
Wood-Dauphinee S, Shapiro S, Bass E, Fletcher C, Georges P, Hensby V, Mendelsohn B. A randomized trial of team care following stroke Stroke 1984 Sep-Oct 15(5):864 72 6382700
Wood-Dauphinee S, Williams J, Shapiro S. Examining outcome measures in a clinical study of stroke Stroke 1990 May 21(5):731 9 2339453
World Health Organization (WHO). International classification of impairments, disabilities, and handicaps (ICDIDH), Geneva: World Health Organization;1980
World Health Organization. Stroke-1989: Recommendations on stroke prevention, diagnosis, and therapy; report of the WHO Task Force on Stroke and other Cerebrovascular Disorders Stroke 1989 Oct 20(10):1407 31 2799873
Yano K, Reed DM, MacLean CJ. Serum cholesterol and hemorrhagic stroke in Honolulu Heart Program. Stroke. 1989;20:1460-4. [pmid: 2815179].
Yekutiel M, Guttman E. A controlled trial of the retraining of the sensory function of the hand in stroke patients. J Neurol Neurosurg and Psychiatry. 1993;56:241-4. [pmid: 8459238]. [pmcid: 1014854].
Yesavage JA, Brink TL, Rose TL, Lum O, Huang V, Adey M, Leirer VO. Development and validation of a geriatric depression screening scale: a preliminary report J Psychiatr Res 1982-83 17(1):37 49 7183759
Young JB, Forster A. The Bradford community stroke trial: eight week results. Clin Rehabil. 1991;5:283-92.
Young JB, Forster A. The Bradford community stroke trial: results at six months. BMJ. 1992 Apr;304:1085-9. [pmid: 1586821]. [pmcid: 1881935].
Zung WK, Richards CB, Short MJ. A self-rating depression scale. Arch Gen Psychiatry. 1965 Jan;12:63-70. [pmid: 14221692].