# Executive Summary

## Introduction

Stroke is the third leading cause of death in the United States and the leading cause of disability among adults. Approximately 550,000 people suffer strokes each year and nearly 150,000 people die from them, while 3 million people are alive following strokes with varying degrees of neurological impairment. Consequent burdens in human and economic terms are enormous.

Brain infarctions account for about three-quarters of strokes and intracerebral or subarachnoid hemorrhages for about 15 percent; the remainder are of other or unknown causes. Stroke frequency increases dramatically with increasing age, doubling with every decade after 55 years of age. Men experience strokes more frequently than women and African Americans more frequently than whites. Mortality from stroke in different reports ranges from 17 to 34 percent in the first 30 days and from 25 to 40 percent in the first year. Stroke mortality has declined in recent years due to a combination of better acute care, reduced stroke severity, and earlier and more accurate diagnosis. Important modifiable risk factors include hypertension, cigarette smoking, atrial fibrillation, left ventricular hypertrophy, and transient ischemic attacks.

Hemiparesis is a presenting finding in three-quarters of patients. Acute neurological impairments frequently resolve spontaneously, but persisting disabilities lead to partial or total dependence in activities of daily living in 25 to 50 percent of stroke survivors.

Disablement has been conceptualized by the World Health Organization in terms of impairment (organ dysfunction), disability (difficulty with tasks), and handicap (social disadvantage). Rehabilitation is a restorative and learning process which seeks to hasten and maximize recovery from stroke by treating the resultant impairments, disabilities, and handicaps. It attempts to help the patient regain freedom of movement and functional independence and to reintegrate as fully as possible into community life.

The goal of this guideline is to improve the effectiveness of stroke rehabilitation by identifying the most effective methods of assessing and treating people who have disabilities due to stroke. The primary focus is on the patient with a first stroke who has developed hemiparesis with or without other neurological impairments. Recommendations refer to each stage of recovery, from the acute hospitalization through subsequent rehabilitation and return to a community residence. Target audiences for the guideline are practitioners who care for the stroke survivor during this period, and include both primary care physicians and rehabilitation professionals.

Scientific data supporting the effectiveness of rehabilitation programs and interventions in improving patient outcomes are limited. Wherever available, these data are used to support recommendations; where they are not available, reliance is placed on expert opinion. The need for post-stroke rehabilitation practice guidelines is underscored by the magnitude of the problem of disability from stroke, and also by wide variations in rehabilitation practices in the United States. Practice guidelines can help to reduce practice variations while, at the same time, encouraging better documentation of the benefits of rehabilitation services and implementation of the research that is needed to put stroke rehabilitation on a firm scientific footing.

## Recommendations for Patient Management

### Basic Principles of Rehabilitation

#### Interdisciplinary Care

Stroke rehabilitation frequently involves the services of several rehabilitation disciplines. The skills required depend on the nature of the patient's neurological deficits. Medical specialties that are commonly involved include physical medicine and rehabilitation (physiatry), neurology, geriatrics, internal medicine, psychiatry, and family practice. Consulting physicians from other specialties are called on as needed. Therapists include persons specializing in occupational therapy, physical therapy, psychology and neuropsychology, recreational therapy, and speech-language pathology. Other professionals who commonly participate include rehabilitation nurses, physician assistants, social workers, and dietitians. In many programs, physicians and rehabilitation clinicians work together as an interdisciplinary team.

#### Patient Assessment

Thorough, consistent, and fully documented assessment is required throughout the rehabilitation process. Assessment needs to include both repeated clinical examinations and the use of standardized instruments. Primary targets of assessment are neurological deficits; medical problems; physical, cognitive, emotional, and speech and language disabilities; and impediments to community reintegration. In the latter respect, assessment of the living environment, family functioning, and community supports is important. Assessment measures need to be valid, sensitive, and reliable if they are to measure progress accurately. This guideline recommends assessment protocols for each phase of rehabilitation and includes only the better validated measurement instruments.

Continuity of Care. The typical stroke survivor receives care in multiple settings during the course of recovery. Care that begins in the acute hospital is continued in inpatient (hospital or nursing facility), home, or outpatient rehabilitation programs, or by the family and the patient's personal physician or other health care provider after discharge. Since any change in treatment setting is accompanied by an increased risk of gaps in care, close communication among providers and between providers and the patient and family is essential. Thorough documentation and transfer of clinical information are especially important.

#### Patient and Family Involvement

Stroke survivors and, when relevant, families need to be fully informed and intimately involved in all rehabilitation decisions--the selection of rehabilitation setting, determination of rehabilitation goals and interventions, and choice of community residence. Rehabilitation is a learning experience in which both the patient and family are active participants. Ample opportunity needs to be given to address questions and concerns and to ensure adequate preparation during each stage of recovery.

### Rehabilitation During the Acute Hospitalization

Stroke rehabilitation should begin as soon as the diagnosis of stroke is established and life-threatening problems are under control. Highest priorities are to prevent complications from the present stroke, prevent recurrent stroke, and mobilize the patient and encourage resumption of self-care activities as soon as medically feasible.

A considerable body of evidence, mainly from countries in Western Europe, indicates that better clinical outcomes are achieved when patients with acute stroke are treated in a setting that provides coordinated, multidisciplinary stroke-related evaluation and services. Skilled staff, better organization of services, and earlier implementation of rehabilitation interventions appear to be important components.

The value of early mobilization has been amply demonstrated. Measures should begin with range-of-motion exercises and physiologically sound changes of position in bed on the day of admission, and should be followed by progressively increased levels of activity as soon as medically tolerated. Early mobilization also includes encouragement to resume self-care activities and socialization.

Etiologic-specific measures to prevent recurrent stroke should be implemented in all patients. Evidence of effectiveness is especially strong for carotid endarterectomy in patients with 70 to 99 percent obstruction of the carotid artery, use of anticoagulants in patients with nonvalvular atrial fibrillation or other cause of cardiac embolic stroke, and use of antiplatelet agents in patients who have had a transient ischemic attack (TIA).

The value of low-molecular-weight (LMW) heparin or low-dose heparin (LDH) to prevent deep vein thrombosis in immobilized patients with stroke is well supported. Warfarin, intermittent pneumatic compression, and elastic stockings are also effective. Appropriate measures should be implemented in all immobilized patients.

Swallowing problems (dysphagia) are common after stroke and may cause aspiration. The patient's ability to swallow should be assessed before oral intake is begun, and techniques to facilitate swallowing should be implemented in affected patients. A feeding gastrostomy or nasogastric tube may be required if the patient does not regain the ability to swallow safely.

Patients who have had seizures after stroke should be given anticonvulsant medication to prevent recurrent seizures. Maintenance of skin integrity, fall prevention, and management of bowel and bladder function are important. Indwelling urinary catheters should be used only with patients who cannot be otherwise managed and should be removed as soon as possible to avoid urinary tract infections or other complications.

Patient and family support and education are intrinsic components of acute care for stroke. Adequate understanding of the cause and manifestations of the stroke, its treatment, and the prognosis are particularly important, as is counseling to help the patient and family deal with their concerns. Discharge planning extends support and education, identifies a postdischarge setting, and seeks to ensure continuity of care.

### Screening for Rehabilitation and Choice of a Setting

All stroke survivors need caring, support, and education, but only some need formal rehabilitation. People who recover completely from their strokes will not need rehabilitation, and others will be too incapacitated to benefit from rehabilitation. Between these extremes are people with varying degrees of disability. For these individuals, the goal should be to identify the best possible match between their needs and the capabilities of available rehabilitation facilities.

A screening examination for rehabilitation should be performed as soon as the patient's medical and neurological condition permit by a person who is experienced in rehabilitation and has no direct financial interest in the referral decision. The screening examination uses information recorded in the medical record, but also needs to include direct examination of the patient and use of a well-standardized disability (e. g., activities of daily living) instrument and mental status screening test.

Threshold criteria for admission to a comprehensive rehabilitation program are medical stability, the presence of a functional deficit, the ability to learn, and enough physical endurance to sit supported for at least 1 hour and to participate actively in rehabilitation to at least some extent. Admission to an interdisciplinary program should be limited to patients who have more than one type of disability and who therefore need the services of two or more rehabilitation disciplines; patients with a single disability can benefit from individual services, but do not need an interdisciplinary program.

Stroke rehabilitation can be conducted in inpatient rehabilitation hospitals or rehabilitation units in acute care hospitals, in nursing facilities with rehabilitation programs, in outpatient facilities, or in the home. Hospital programs are usually the most comprehensive and intense and have the best medical coverage. A few nursing facility programs are similar to hospital programs, but many are less comprehensive. The wide variability in the capabilities of nursing facility programs makes it incumbent on the referring physician or hospital to evaluate the capabilities of the program with specific reference to each patient's needs. Outpatient and home rehabilitation programs also vary widely in their comprehensiveness and intensity.

Patients who are medically unstable are not suitable for any rehabilitation program. Those who have complex medical problems that require frequent attention are usually better treated in facilities that have round-the-clock coverage not only by rehabilitation nurses and physicians, but also immediately available consultant services by other medical specialists. Patients with moderate or severe disabilities and sufficient physical endurance to tolerate intense rehabilitation (at least 3 hours of physically demanding exercises per day) are candidates for intense hospital or nursing facility programs. Patients with milder degrees of disability and those who have poor physical endurance or limited attention spans are usually better served by lower intensity programs in nursing facilities, at home, or in outpatient facilities. The characteristics of the home environment and availability of social support may affect the feasibility of home or outpatient rehabilitation; for the latter, availability of transportation can also be a constraint. In some instances, a further period of recuperation in a nursing facility or at home will allow enough recovery for a patient to enter a comprehensive rehabilitation program at a later time. Providers need to remain alert to these opportunities, and patients and families should be made aware that reassessment could occur in the future, leading to a change in treatment.

### Managing Rehabilitation

#### Assessment

A summary of the patient's previous medical record and information collected during the screening examination should be available at the time of admission to any rehabilitation program, so that changes in the patient's condition can be identified and questions about medical management can be resolved promptly.

A thorough baseline rehabilitation evaluation should be completed within 3 working days of admission to an intense rehabilitation program (hospital or nursing facility), within 7 days of admission to a lower intensity nursing facility program, and within three visits in the case of an outpatient or home rehabilitation program. The initial history and physical examination by a physician and a nurse should be done within 24 hours or during the first visit. These timelines, reflecting expert opinion, attempt to establish a reasonable balance between feasibility and the need for prompt treatment.

#### Setting Rehabilitation Goals and Developing the Rehabilitation Management Plan

Rehabilitation goals should be realistic in terms of current levels of disability and potential for recovery, and should be mutually agreed to by the patient, family, and rehabilitation professionals. It is important that goals be recorded in the medical record in explicit, measurable terms so that they can serve as yardsticks against which to measure the patient's progress during rehabilitation. The rehabilitation management plan specifies measures to prevent recurrent stroke and complications; treatments for comorbidities; and rehabilitation interventions with their sequence, intensity, frequency, and expected duration.

#### Monitoring Progress

The patient's progress should be monitored regularly during rehabilitation--weekly during intense inpatient rehabilitation in a hospital or nursing facility and at least every other week during less intense nursing facility, home, or outpatient programs. Clinical examinations and standardized instruments that focus on impairments or disabilities being treated should be used. The information obtained is valuable in measuring progress toward goals, identifying the need for changes to treatment regimens, and, ultimately, guiding discharge decisions.

#### Managing Functional Health Patterns

Management of dysphagia; maintenance of nutrition, hydration, and skin integrity; and management of bowel and bladder function remain as important as they were during acute care. Sleep disturbances are common and should receive cause-specific treatment.

#### Managing Sensorimotor Deficits

Patients with motor deficits but some motor control should be encouraged to move the affected limb in functional tasks and offered exercises and training directed at improving strength and motor control and improving performance. Available research evidence does not, however, support any superiority of neuromuscular facilitation over traditional physical therapy exercises, nor does it adequately support the value of biofeedback or functional electrical stimulation in enhancing responses to physical therapy.

#### Compensatory Training

Patients with persistent functional deficits should be taught new approaches to performing important tasks of daily living, using the affected limb when possible or, when not, the unaffected limb. This recommendation is supported primarily by expert opinion and applies to the performance of a wide range of tasks including self-care (ADL) tasks; more complex tasks required during independent living such as the use of the telephone and public transportation, driving a car, and financial management; and performance of social and recreational activities, spiritual roles, and work. Adaptive devices should be used if other methods to perform the task are not available or cannot be learned, and to facilitate task performance if easy fatigability or patient safety are factors.

#### Managing Cognitive and Perceptual Deficits

Cognitive and perceptual deficits increase the severity of functional deficits, affect rehabilitation goals, and require highly goal-directed rehabilitation plans.

#### Diagnosing and Treating Depression

Depression is common after stroke. Diagnosis requires a high level of suspicion and a thorough clinical examination by a mental health professional. Depression scales are useful for screening and for monitoring responses to treatment, but should not be relied on for diagnosis. The choice of treatment depends on the cause of depression, the severity of symptoms, and responses to treatment. Drug treatment, psychotherapy, or a combination may be needed in patients with major depression; mild depression often responds to counseling and encouragement. Initial doses of drugs should be small, and the patient should be closely monitored for side effects.

#### Managing Speech and Language Disorders

Problems in functional communication are common after stroke. Thorough evaluation requires the use of standardized evaluation measures. A variety of approaches to treatment have been used in patients with aphasia and appear to be effective in some patients. However, treatments of right hemisphere communication disorders, dysarthria, and apraxia of speech have been less extensively studied.

#### Discharge Planning

Discharge planning should begin on the day of admission. It should be coordinated by one person, but should involve the stroke survivor, family/caregivers, and relevant rehabilitation professionals. Goals are to identify a safe place of residence, ensure adequate patient and family education, and arrange for continued medical care, rehabilitation, and community services. Decisions ideally reflect a consensus of all involved parties.

Discharge from an inpatient rehabilitation program should be considered when rehabilitation goals have been achieved or when 2 weeks have elapsed without documented progress. Under these circumstances, transfer to another level of care or discharge is usually in the patient's best interests and also represents a cost-effective use of rehabilitation resources. Exceptions occur when there is a clear explanation for a temporary functional plateau.

Assessments prior to discharge include evaluation of the patient's functional status, adequacy of the proposed living environment, adequacy of support by family or other caregivers, and availability of community supports.

### Transition to the Community

Return to a community residence after an acute hospitalization for stroke, or after an inpatient rehabilitation program, can be difficult for the stroke survivor and family alike. At this time, the person has to assume increased responsibility for independent functioning in the absence of the supportive environment of the inpatient setting, with the family or other caregivers providing needed support. Continuity of services is important during this period, and patient and family counseling may be needed to facilitate family functioning and improve outcomes.

The patient's continuing needs for medical care and rehabilitation should be coordinated by a single clinician in collaboration with the individual and family. An initial visit with this care coordinator should be scheduled no later than 1 month after discharge. Close communication among providers, the patient, and the family is critical to developing a coherent care plan and avoiding gaps or inconsistencies in care.

After the return to a community residence, progress needs to be evaluated at regular intervals to document whether the person is maintaining gains made during rehabilitation, progressing toward more independent function, and successfully reintegrating with the family and community.

Rehabilitation services generally should be phased out slowly after completion of hospital or nursing facility rehabilitation programs or during home or outpatient programs to avoid the feeling of abandonment and provide opportunities for "tuneups." Continued rehabilitation services should be justified, however, by documented evidence of progress.

Community supports are important for many stroke survivors. Acute care hospitals and rehabilitation facilities should maintain up-to-date information on community resources and offer assistance to patients and their families in obtaining needed services. Individual health care providers should be familiar with available services and sources of information.

Issues that arise after return to a community residence include safety and fall prevention, health promotion, sexuality, resumption of leisure and community activities, driving, and return to work. Each of these areas needs to be carefully addressed.

## Research Priorities

Research is needed to fill gaps in knowledge regarding the effectiveness of stroke rehabilitation. Highest priority should be given to well-controlled experimental studies that assess functional and quality-of-life outcomes and the cost effectiveness of alternative service delivery strategies.

Goals should be to:

- Identify the characteristics of patients who are most likely to benefit from rehabilitation interventions.
- Determine the optimal type of rehabilitation program for different types of patients.
- Identify factors that affect the optimal timing, intensity, and duration of rehabilitation.
- Determine the effectiveness of specific treatments or combinations of treatments in reducing impairments and improving function.
- Develop and validate standardized tests for use in monitoring post-stroke rehabilitation.