# Acknowledgments

The panel and project director wish to give special thanks to the individuals, professional groups, and members of the rehabilitation facilities that contributed their time and expertise to the development of this guideline.

Several consultants to the panel helped immeasurably in identifying key issues, compiling relevant literature, and critiquing manuscript drafts of the guideline. These persons were Robert Berrian, CTRS, Director of Recreational Therapy Services, Health South Rehabilitation Center, Pennsylvania; Richard W. Bohannon, EdD, PT, University of Connecticut; James S. Liljestrand, MD, Medical Director, Braintree Hospital, Massachusetts; and, Fay W. Whitney, RN, PhD, FAAN, School of Nursing, University of Pennsylvania.

Thomas C. Chalmers, MD, and Sidney Klawansky, PhD, MD, both from the Harvard School of Public Health, conducted the initial literature searches and performed meta-analyses on the benefits of stroke units, biofeedback, and functional electrical stimulation. These studies provided useful insights that facilitated interpretation of the scientific literature.

Expert peer reviewers of an early manuscript version of the guideline provided invaluable assistance in refining recommendations and marshalling additional supporting evidence from the scientific literature. The comprehensiveness of these reviews was outstanding. Professional organizations that reviewed the guideline documents, and practitioners and rehabilitation facilities who performed pilot testing, offered many constructive comments that we hope and expect will facilitate acceptance of the guideline's recommendations.

Ann Venable's expert editorial skills were essential to creating the AHCPR-sponsored Clinical Practice Guideline and Quick Reference Guide for Clinicians from a much longer Guideline Technical Report, and to writing the Patient and Family Guide (consumer version). We also wish to thank A. James Lee, PhD, for managing the project at the Center for Health Economics Research (Massachusetts), and Cheryl S. Lewis; Carol Ammering; Monika Reti; Holly Cyr; Joyce Huber, PhD; Helen Margulis; Robyn Tarantino; Philip W. Tyo; Adam Falk; and Amy Rensko for their able technical assistance.

We would like to thank David C. Lanier, MD, for his guidance and encouragement throughout the guideline's developmental process. He served as the project officer from the Office of the Forum for Quality and Effectiveness in Health Care, AHCPR. We are also grateful to Timothy F. Campbell of AHCPR for serving as managing editor of the guideline documents, and to Valna Montgomery for serving as AHCPR's product manager.