# Panel Members

- Glen E. Gresham, MD
- Chair
- Professor and Chairman
- Department of Rehabilitation Medicine
- State University of New York at Buffalo
- Director of Rehabilitation Medicine
- Erie County Medical Center
- Buffalo, NY
- Specialty: Internal Medicine

- Pamela W. Duncan, PhD, PT
- Co-Chair
- Associate Professor
- Health Services Administration
- University of Kansas
- Director of Research
- Center on Aging
- Kansas University Medical Center
- Kansas Ay, KS
- Specialty: Physical Therapy; Epidemiology; Health Services

- Harold P. Adams, Jr., MD
- Professor of Neurology and Director
- Division of Cerebrovascular Diseases
- University of Iowa College of Medicine
- Iowa Ay, IA
- Specialty: Neurology

- Alan M. Adelman, MD, MS
- Associate Professor and Director of Research
- Department of Family and Community Medicine
- Pennsylvania State University
- The Milton S. Hershey Medical Center
- Hershey, PA
- Specialty: Family Practice

- David N. Alexander, MD
- Director of Stroke Rehabilitation
- Center for Diagnostic and Rehabilitation Medicine
- Daniel Freeman Hospital
- Assistant Clinical Professor
- Department of Neurology
- University of California at Los Angeles School of Medicine
- Los Angeles, CA
- Specialty: Neurology

- Duane S. Bishop, MD
- Director, Rehabilitation Psychiatry
- Rhode Island Hospital
- Associate Professor
- Department of Psychiatry
- Brown University
- Providence, RI
- Specialty: Psychiatry

- Leonard Diller, PhD
- Chief and Professor
- Behavioral Science and Clinical Rehabilitation Medicine
- Rusk Institute of Rehabilitation Medicine
- NYU Medical Center
- New York, NY
- Specialty: Psychology

- Nancy E. Donaldson, RN, DNSc
- Consumer Representative
- Newport Beach, CA
- Specialty: Spousal/Family Caregiving--Consumer Perspective

- Carl V. Granger, MD
- Professor and Director
- Rehabilitation Medicine and Center for Functional Assessment Research
- State University of New York at Buffalo
- Buffalo, NY
- Specialty: Physiatry

- Audrey L. Holland, PhD
- Professor and Head
- Department of Speech and Hearing Sciences
- University of Arizona
- Tucson, AZ
- Specialty: Speech and Hearing Sciences; Speech-Language Pathology

- Margaret Kelly-Hayes, EdD, RN, CRRN
- Research Coordinator and Investigator
- Neuroepidemiology Section
- Department of Neurology
- Associate Clinical Professor of Neurology (Neurological Nursing)
- Boston University School of Medicine
- Boston, MA
- Specialty: Rehabilitation Nursing and Epidemiology

- Fletcher H. McDowell, MD
- Executive Medical Director
- Burke Rehabilitation Hospital
- White Plains, NY
- Associate Dean and Winifred Masterson Burke Professor of Neurology and Rehabilitation Medicine
- Cornell University Medical College
- New York, NY
- Specialty: Neurology

- Larry R. Myers, MD
- Family Practitioner Clinician
- Ambulatory Sentinel Practice Network
- Community Preceptor
- Mansfield, TX
- Specialty: Family Practice

- Marion A. Phipps, RN, MS, CRRN, FAAN
- Rehabilitation Nurse Specialist
- Beth Israel Hospital
- Boston, MA
- Specialty: Rehabilitation Nursing

- Elliot J. Roth, MD
- Medical Director
- Rehabilitation Institute of Chicago
- Professor
- Department of Physical Medicine and Rehabilitation
- Northwestern University Medical School
- Chicago, IL
- Specialty: Physiatry

- Hilary C. Siebens, MD
- Medical Director
- Skilled Nursing and Assessment Center
- Medical Director
- Rehabilitation Research
- Cedars-Sinai Medical Center
- Assistant Clinical Professor
- Department of Medicine
- Division of Physical Medicine and Rehabilitation
- University of California at Los Angeles
- Los Angeles, CA
- Specialty: Geriatrics Physiatry

- Gloria A. Tarvin, MSW, LSW
- Chairperson of Allied Health/Nursing and Director of Social Work
- Rehabilitation Institute of Chicago
- Chicago, IL
- Specialty: Social Work

- Catherine Anne Trombly, ScD, OTR/L, FAOTA
- Professor of Occupational Therapy
- Sargent College of Allied Health Professions
- Boston University
- Boston, MA
- Specialty: Occupational Therapy