# Foreword

This guideline was developed to assist primary care providers and rehabilitation specialists in the care of patients with disabilities from stroke and to help patients and their families become better informed consumers of rehabilitation services. The guideline seeks to increase awareness of the value and limitations of rehabilitation treatments after stroke and to encourage appropriate use of services.

Stroke is a leading cause of disability in the elderly and a significant cause of disability in younger people. Nearly 3 million Americans have some degree of disability from strokes, and the estimated annual economic burden is more than $30 billion. Rehabilitation attempts to reduce levels of disability and facilitate return to active and productive lives through a combination of educational, counseling, physical, and technology-based interventions. Prevention of recurrent strokes and prevention of complications from stroke are additional objectives. Rehabilitation combines a medical/scientific orientation with a social service orientation. Caring, support, and advocacy for the disabled are intrinsic components.

This guideline focuses primarily on the patient with a first stroke who has some degree of hemiparesis, with or without other neurological deficits, and is a candidate for treatment in an interdisciplinary rehabilitation program. Many recommendations also apply, however, to people with multiple strokes and those with limited disabilities who require care by a single rehabilitation discipline. Recommendations cover the period from the time of admission to an acute care hospital through any rehabilitation program and the transition to a community residence.

The benefits of rehabilitation must be distinguished from spontaneous neurological recovery after a stroke. For this reason, the natural history of recovery from stroke is emphasized. Recommendations address rehabilitation interventions during acute care, assessment strategies throughout acute care and rehabilitation, the choice of a rehabilitation setting, goal setting and management during rehabilitation, and issues that arise after the patient returns to a community residence. Recommendations are explicit where this is possible; otherwise, they imply a sense of priority or direction. Recommendations are supported by direct evidence from controlled trials where this is available. However, the sparsity of good scientific evidence has necessitated heavy reliance on expert opinion to support most recommendations.

The guideline was developed by the Center for Health Economics Research in Waltham, Massachusetts, under a contract with the Agency for Health Care Policy and Research (AHCPR). Development was led by a multidisciplinary panel of experts. Inputs included an extensive review of relevant literature, public testimony at a national public forum, and thorough review by a wide array of additional experts, professional organizations, and rehabilitation facilities. These multiple levels of review substantially shaped the final document.

It is important to emphasize that this guideline is a first attempt to codify stroke rehabilitation practice. We hope it will provide useful guidance. Additional research is urgently needed to put stroke rehabilitation on a firm scientific footing. Results of this research need to be incorporated into revisions of the guideline.

Post-Stroke Rehabilitation Guideline Panel