# Transition to the Community

Living with disabilities after a stroke is a lifelong challenge during which people continue to seek and find ways to compensate for or adapt to persisting neurological deficits. For many stroke survivors and their families, the real work of recovery begins after formal rehabilitation. One of the most important tasks of a rehabilitation program is to help those involved to prepare for this stage of recovery.

Many people live on their own after a stroke. Others live with family members who will need to provide various kinds of support. The impact of every stroke is intensely individual, and each person and family has to chart a pathway to recovery. This chapter focuses mainly on the patient who lives with caregivers and on common themes that arise after return to a community residence.

## The Transition Experience

The first few weeks after discharge from a rehabilitation program are often difficult, as the stroke survivor attempts to use newly learned skills without the support of the rehabilitation environment. Later on, other problems may emerge when the full impact of stroke becomes apparent as the person attempts to resume self-care activities and family relationships. Psychological and social effects of the stroke, such as communication disorders or limitations of short-term memory, are likely to become more obvious over time and may have profound effects on daily life.

Coping with this transition requires both preparedness and flexibility. The stroke survivor and family should be thoroughly prepared by discussion of transition issues before discharge, accompanied, whenever possible, by visits to the home by rehabilitation professionals to plan how specific activities will be accomplished. At the same time, they need to be able to respond to the unexpected. Most people rely on well-used, proven methods of problem solving that become automatic. During the first weeks following discharge from a program, stroke survivors and their caregivers may discover that familiar and comfortable approaches do not work well. This realization should be a cue to seek new information, insights, or resources. Flexibility and willingness to seek creative problem-solving methods will be the key.

## Family and Caregiver Functioning

Recommendation: Clinicians need to be sensitive to potential adverse effects of caregiving on family functioning and the health of the caregiver. They should work with the patient and caregivers to avoid negative effects, promote problem solving, and facilitate reintegration of the patient into valued family and social roles. (Research evidence = B; expert opinion = strong consensus.)

Support by family members or other caregivers is critical to achieving the best possible long-term outcomes for individuals with disabilities. The term family applies to people with whom the person has lived or will live, including extended family members. For older people, this will often be the spouse (but children, other relatives, or friends may also constitute the family). For younger people with stroke, parents and siblings may constitute the family unit. The term caregiver is used to identify the one or two individuals who provide most of the support, whether they are family members, close friends, or from a community agency. The majority of caregivers of stroke survivors are women.

Caring for a person with severe disabilities can be a formidable task. Impairments in mobility may tax an elderly spouse's physical strength and endurance; and cognitive, emotional, and communication problems often have pervasive effects on family and social relationships. In general, caregivers cope with physical limitations better than cognitive or emotional ones (Evans, 1986). However, even healthy and committed caregivers may "burn out" from the continuous pressure of providing support to a patient 24 hours a day, 7 days a week. Opportunities for respites may be extremely important.

Adverse health effects on caregivers have been well documented; they include increased risk of depression (Blazer, Hughes, and George, 1987; Kramer, German, Anthony, et al., 1985; Lichtenberg and Barth, 1990; Schultz, Uisintainer, and Williamson, 1990), increased use of health services, and the self-administration of medications prescribed originally for the stroke patient (Lichtenberg and Gibbons, 1992). Depression, in turn, has been associated with physical abuse of the patient (Joslin, Coyne, Johson, et al., 1991) and a greater likelihood of nursing home placement (Stephens, Kinney, and Igrocki, 1991). As many as 14 percent of employed caregivers of people with strokes have been reported to leave their jobs (Brocklehurst, Morris, Andrews, et al., 1981). Female caregivers are more likely to experience depression and serious lifestyle disruptions (Evans, Hendricks, Lawrence-Umlauf, et al., 1989).

Despite the difficulties, many caregivers and families function extremely well (Bishop, Epstein, Keitner, et al., 1986). Preexisting organizational and functional characteristics of the family may have important effects on the outcome (Bishop, Epstein, Keitner, et al., 1986; ; Freidland and McColl, 1987; Gwyther and George, 1986; Jimenez and Morgan, 1979; Robinson, Bolduc, and Kubos, 1985; Susset, Vobecky, and Black, 1979). A caregiver is more likely to give adequate support if she or he is a spouse who is knowledgeable about stroke and its disabilities, is not depressed, and lives in an otherwise well-functioning family unit (Evans, Bishop, and Dusley, 1992). Families that have a history of adaptive coping, extensive social supports, and strong functional and affective mutuality usually function well. On the other hand, family patterns of constricted emotional responsiveness and rigid expectations about standards of behavior for cognitively impaired individuals are associated with more days of rehospitalization after a stroke (Evans, Bishop, Matlock, et al., 1987b). Pre-stroke family functioning has been shown to affect adherence to treatment (Evans, Bishop, Matlock, et al., 1987a), psychosocial adjustment (Evans, Bishop, Matlock, et al., 1987b), caregiver adjustment (Evans, Bishop, and Haselkorn, 1991), and the likelihood of nursing home placement (Evans and Noonan, 1988).

Cultural factors may have important effects on attitudes about disability, the roles of family members during transition, and the ability of the family to deal with the complexities of the health care system. Barriers may be especially difficult to circumvent if the family has a different cultural orientation from that of the community at large. Sensitive counseling can help families with decisions that run counter to traditional values.

Chapters 4 and 6 stressed the importance of patient and family/ caregiver education during acute care and rehabilitation. Table 25 summarizes the results of studies of educational and support interventions offered during community transitions. The most impressive result was obtained by a study that examined the effects of reinforcing key educational messages and offering counseling to caregivers after the stroke survivor returns home (Evans, Matlock, Bishop, et al., 1988). In this study, one group of patients received education directed at improving the caregiver's ability to provide support, and another received education plus later counseling sessions to explore problems and reinforce previous education. Both experimental groups performed better than a control group, but benefits were sustained only in the group that received followup sessions. A related study demonstrated that participation of caregivers in problem-solving groups reduced the likelihood of depression compared to supportive groups (Lovett and Gallager, 1988).

Table 25. Evidence on the effectiveness of patient and family education and support interventions

Author, Year, Country | Purpose, Study design Duration of deficits Number of subjects | Outcome measures Maximum followup | Conclusions/Comments
Friedland and McColl (1992) Canada | Determine if a social support intervention (SSI) increases support and psychosocial outcomes RCT Chronic deficits N = 88 | Social Support Inventory Interpersonal Support Evaluation List General Health Questionnaire (GHQ) Sickness Impact Profile (SIP) ADL (Barthel) F/U until 6 months | No significant differences among groups.
Jongbloed and Morgan (1991) Canada | Compare OT visits to assist in leisure activities to single OT home visit RCT Deficits < 15 months N = 40 | Katz Adjustment Index Free-time activities Satisfaction with activities F/U until 18 weeks | No significant differences.
Pain and McLellan (1990) United Kingdom | Test benefits of individualized booklets given to patients at discharge from rehabilitation RCT Duration of deficits not available N = 36 | ADL (Barthel) Frenchay Activities Index Caregiver Questionnaire F/U until 3 months | No significant function or differences on activities.
Towle, Lincoln, and Mayfield (1989) United Kingdom | Examine effects of a social worker intervention on use of health and social services RCT Chronic deficits N = 44 | Use of health and social services Financial benefits Extended ADL (EADL) Frenchay Activities Index F/U until 16 weeks | No significant differences on any measure.
Evans, Matlock, Bishop, et al. (1988) United States | Examine effects of caregiver education with and without additional counseling RCT Acute deficits N = 188 | Stroke Care Information Test (SCIT) Family Assessment Device (FAD) ESCROW Profile (social resources) Personal Adjustment and Role Skills Scale (PARS) F/U until 1 year | Both counseling and education significantly improved family functioning and caregiver knowledge. Counseling more effective than education alone and also resulted in better patient functioning. Neither intervention affected use of social resources.

Note: ADL = activities of daily living, F/U = followup, OT = occupational therapy, RCT = randomized controlled trial.

Clinical followup should include assessment of caregiver and family functioning. An initial visit within 1 month of discharge will permit early identification of any problem areas and the development of education or counseling interventions to address them or efforts to obtain support from community sources. Responsibility for followup may rest with the stroke survivor's principal physician or may be delegated to a rehabilitation specialist who is providing continued services after discharge. Whoever performs this function, active involvement of the stroke survivor and family and continuity with previous education or counseling services are necessary.

## Continuity and Coordination of Patient Care

Recommendation: The stroke survivor's continuing care needs should be coordinated by a single physician or health care provider with the stroke survivor and the principal caregiver. (Research evidence = NA; expert opinion = strong consensus.)

The return to community living confronts the stroke survivor and caregivers with the sometimes formidable task of maintaining continuity with previous services and coordinating the broad range of medical, rehabilitative, and social services required by many persons with disabilities. Gaps in care will increase the risk of reinstitutionalization, and discontinuities in treatment regimens may slow progress toward functional independence. The importance of well-coordinated aftercare is accentuated by trends toward earlier discharges from both acute care and rehabilitation hospitals.

Responsibility for coordinating medical and health services during transition passes to the patient's principal physician or health care provider; outpatient or home care rehabilitation services often replace inpatient or nursing facility programs; and the stroke survivor and family/caregivers assume responsibility for daily activities. Each of these transitions requires careful planning and close communication among the parties involved.

The key players in the transition process are the stroke survivor, principal caregiver, and the primary physician or health care provider. The stroke survivor or the principal caregiver coordinates all issues, information, and actions. Occasionally, the physician, social worker, or visiting nurses will perform this function. This person should be identified as soon as possible after an acute stroke and should be fully knowledgeable concerning the stroke survivor's needs and resources.

The principal physician may be from any of a variety of medical specialties, but will most commonly be the patient's physician prior to the stroke or a rehabilitation specialist. This person is responsible for providing general medical services, coordinating medical specialty and rehabilitative services, and assessing the patient's progress. In many States, this person is legally required to certify disabilities and the patient's ability to drive an automobile. The advantages of involving a physician who is skilled in rehabilitation medicine should be considered, especially in the face of moderate or severe disabilities that require continued rehabilitation services.

Close communication among providers, the stroke survivor, and family/caregivers is essential at each stage. As a first step, a complete discharge summary should be given to the principal physician on the day of discharge. Table 26 lists the types of information that should be included.

Table 26. Information to be included in discharge summary following rehabilitation

- Patient's medical history, including functional status prior to stroke and on admission to rehabilitation; - Current physical examination and clinical course including complications experienced, diagnoses, and current medical and rehabilitative treatment regimens.; - Type, intensity, and duration of interventions received during rehabilitation and functional responses to these.; - Continuing requirements for support in mobility, functional health patterns, and performance of self-care activities.; - Anticipated need for medical care and equipment.; - Cognitive, psychological, or behavioral problems experienced, their current treatments, and anticipated future problems.; - Specific recommendations for continued rehabilitation services and a "best estimate" of the functional prognosis.

Subsequently, all clinical information should be centralized in a single patient record. This should include information on progress during rehabilitation therapies and progress toward functional independence, as well as on medical and other health conditions.

Recommendation: An initial visit with the stroke survivor's principal physician or health care providers should be scheduled within 1 month of discharge from an inpatient rehabilitation program or sooner if necessary. (Research evidence = NA; expert opinion = strong consensus.)

To promote continuity of care, appointments with the principal physician and with needed outpatient or home rehabilitation services should be arranged at the time of discharge. An initial followup visit should be scheduled within 1 month of discharge unless medical conditions require earlier attention. In addition, the stroke survivor and family/caregiver should be given a phone contact (hotline) to a person who is familiar with the stroke survivor's condition and should be encouraged to use this at any time if questions or problems arise. Depending on the circumstances, this phone contact may be with the principal physician's office, the discharging rehabilitation program, the visiting nurse, or the community agency providing the services.

## Postdischarge Monitoring

Recommendation: The stroke survivor's progress should be evaluated within 1 month after return to a community residence and at regular intervals during at least the first year, consistent with the person's condition and the preferences of the stroke survivor and family. Monitoring of physical, cognitive, and emotional functioning and integration into family and social roles is especially important. (Research evidence = NA; expert opinion = strong consensus.)

The goals of monitoring are to document whether the stroke survivor is maintaining the functional gains achieved during rehabilitation, making further progress toward functional independence, and reintegrating successfully with the family and community. The period following return to the community is a high-risk time. Gaps in care may occur as responsibility shifts from the rehabilitation program to the principal physician, other rehabilitation services, or community agencies. Moreover, emotional stress, exacerbation of medical conditions, and difficulty in sustaining the level of activities achieved during rehabilitation are common. Regression may occur because of lack of stimulation, lack of confidence, or a physical environment that makes daily activities difficult to perform, or if the family/caregivers inadvertently suppress initiative by taking over rather than encouraging self-performance of activities.

The purpose of postdischarge assessment is to obtain the information needed to guide medical care, promote adjustment to the living environment, identify needs for additional rehabilitation services, and improve the ability of the family or other caregivers to provide support. Types of information to be obtained are identified in Table 27. Especially important are measures of success in adapting to the living environment and functioning independently, adherence to medical and rehabilitation regimens, and the ability of caregivers to provide needed support.

Table 27. Assessment after return to the community

- General; - Neurological deficits.; - Comorbid diseases.; - Stroke-related risk factors.; - Affective disorders.; - Adherence to medical and rehabilitation regimens.; - Functional health patterns: nutrition and hydration, ability to swallow, bowel and bladder continence, skin integrity,activity tolerance, sleep patterns.; - Adaptation; - Patient adaptation and functional performance.; - Family/caregiver functioning.; - Standardized instruments; - Measure of disability (ADL).; - Instrumental activities of daily living (IADL) scale.; - Family Assessment Device.; - Quality-of-life scale.

Note: ADL = activities of daily living.

The use of standardized tests is recommended to evaluate ADL and IADL performance, quality of life, and family functioning. Identification of problem areas in personal or family functioning may indicate the need for additional psychological or social support. A quality-of-life scale is included to assess general well-being and life satisfaction and to identify priorities for future treatment. These instruments should be used in a consistent fashion from one examination to the next, and should be administered by people who are well trained in their administration.

Responsibility for monitoring progress rests with the principal physician, though responsibility for collecting clinical data may be shared with rehabilitation clinicians or community agencies. Evaluations can be performed at the time of medical or rehabilitation visits and can be supplemented by telephone interviews with the stroke survivor or a family member. Initially, a home visit is preferable for patients who remain moderately or severely disabled because of the valuable insights that direct observation can provide into how the individual and family members actually function. The initial evaluation should be performed at the time of the first scheduled followup visit with the physician, within 1 month of discharge. Thereafter, the frequency of evaluation will depend on the needs of the stroke survivor and the family/caregivers. Objectives are to identify areas of disability that may benefit from additional medical or rehabilitation services, counseling, or community services, and to obtain the objective evidence of progress needed to justify continuation of rehabilitation services.

## Continued Rehabilitation Services

Recommendation: Continued rehabilitation services should be considered to help the stroke survivor sustain the gains from the rehabilitation program and to build on patient and family strengths and interests as that patient becomes reintegrated into the home and community. Services should be phased out as measurable benefit diminishes. (Research evidence = NA; expert opinion = consensus.)

Continued rehabilitation services can provide a bridge between the protected environment of the rehabilitation program and independent living. Decisions about such services will depend on the patient's progress during the preceding rehabilitation program and on the level of remaining disabilities. A gradual withdrawal of services rather than sudden cessation is often preferable, since an abrupt end to professional services is often interpreted by patients as an end to improvement (Doolittle, 1992). Followup visits help to identify problems encountered during transition, reinforce expectations of long-term progress, and permit development of a plan to achieve functional independence after the withdrawal of services.

Continued rehabilitation should take full advantage of the patient's and family's strengths and interests, and interventions should be directed at areas of function and activities that are particularly high priorities. These might include, for example, valued hobbies or recreational activities, social relationships, and preexisting family roles. A strong ethnic orientation might provide access to community activities or social groups. The contextual issues summarized in Table 6 (see Chapter 3) become particularly important during transition.

## Community Supports

Recommendation: Acute care hospitals and rehabilitation facilities should maintain up-to-date inventories of community resources, provide this information to stroke survivors and their families/ caregivers, and offer assistance in obtaining needed services. (Research evidence = NA; expert opinion = strong consensus.)

Community supports can help buffer the effects of disabilities on the patient and family/caregivers. Broadly, supports can be categorized as educational, instrumental, or emotional. Educational supports include printed materials, videotapes, computer programs, and information on support groups available from individuals or health professionals, or through organizations such as the American Heart Association and National Stroke Association. Instrumental support refers to physical services such as homemaker services and Meals on Wheels or devices such as ramps or wheelchairs. Emotional support is a broad concept that intrinsically involves people: people to talk to, to turn to for advice, or to seek counsel from. Having people to turn to has been shown to be beneficial even when the advice is rejected (McFarlane, Norman, Streiner, et al., 1983). Strong social support has been shown to improve outcomes, especially in patients with severe strokes (Glass, Matchar, Belyea, et al., 1993). Great attention should be given to opportunities and methods for improving the effectiveness of social support. One such direction is to facilitate linkages and transfer of information between self-help groups and the health care system (Borkman, 1990).

Most social support comes from family, caregivers, and friends. The tendency, however, is for friends and relatives to rally around after the acute stroke, but then dissipate, leaving the person and immediate family to become increasingly isolated over the longer term. Community resources become especially important under these circumstances. Table 28 identifies some national and regional organizations that provide support to persons with stroke and their families. Most of these have local offices or branches in many communities. Availability of additional local resources will vary from community to community. Acute care hospitals and rehabilitation facilities will provide a valuable service if they maintain up-to-date inventories of available resources, and help stroke survivors and families gain access to them.

Table 28. Resources for stroke survivors and families/caregivers

ACTION 1100 Vermont Avenue NW Washington, DC 20525 Telephone: (202) 606-4855 Call for number of regional office | A Federal Agency. Sponsors older American volunteer programs. These include:; - Retired Senior Volunteer Program (RSVP). People age 55 and over are volunteers in schools, libraries, hospitals, and other community settings.; - Senior Companion Program. Volunteers (any age) provide assistance so that low-income people age 60 and over can remain in their homes.; - Foster Grandparent Program. Low-income people age 60 and over are volunteers caring for children with special needs.
Administration on Aging 330 Independence Avenue SW Washington, DC 20201 Telephone: toll-free (800) 677-1116 (Eldercare Locator Number) Call for list of community services for elders in local area | An Agency of the Department of Health and Human Services. Provides community services for people age 60 and over (and spouses, regardless of age). Services are provided by State and area agencies on aging. Services helpful to stroke survivors and families include homemaker services, Meals on Wheels (meals delivered to the home), congregate dining (group meals in a senior center or other community setting), transportation, senior center activities, and information and referrals.
AHA Stroke Connection (formerly the Courage Stroke Network) American Heart Association 7272 Greenville Avenue, Dallas, TX 75231-4596, Telephone: toll-free (800) 553-6321 Or, check telephone book for local AHA office | Operates through national office and through local American Heart Association offices. Provides:; - Educational books, pamphlets, videos, and tapes about stroke for stroke survivors and for families and caregivers.; - Referral to stroke clubs or other self-help groups in stroke survivor's local area.; - Help in starting stroke clubs and other self-help groups.; - Stroke Connection newsletter for stroke survivors and caregivers.; - Stroke of Luck newsletter for stroke survivors with aphasia and caregivers.
American Dietetic Association/National Center for Nutrition and Dietetics 216 West Jackson Boulevard Chicago, IL 60606-6995 Telephone: toll-free (800) 366-1655 (Consumer Nutrition Hotline) | Promotes optimal nutrition, health, and well-being for consumers through its various programs and services:; - Consumers may speak to a registered dietitian for answers to nutrition questions, or obtain a referral to a local registered dietitian.
American Self-Help Clearinghouse, St. Clares-Riverside Medical Center Denville, NJ 07834 Telephone: (201) 625-7101 Call for name and number of State of local clearinghouse National Aphasia Association P.O. Box 1887 Murray Hill Station New York, NY 10156-0611 Telephone: toll-free (800) 922-4622 | Operates through State and local clearinghouses. Provides information on local self-help groups and assistance in starting a self-help group. Operates through national office and local affiliates and promotes national awareness. Provides:; - Educational books and pamphlets about aphasia.; - Referral to community services.
National Easter Seal Society 230 West Monroe Street, Suite 1800 Chicago, IL 60606 Telephone: (312) 726-6200 Or, check telephone book for local Easter Seal Society | Provides information and services to help people with disabilities, including those from stroke. Operates through national office and local Easter Seal Societies. Provides:; - Educational books, pamphlets, and audiovisual aids about disabilities.; - Posters and other publicity to educate the public about people with disabilities.; - Rehabilitation services including physical, occupational, and speech therapy.; - Guidance about assistive devices (such as wheelchairs). Vocational evaluation, training, and placement.; - Recreational and social services.; - Catalog of publications and products.
National Stroke Association 8480 East Orchard Road, Suite 1000 Englewood, CO 80111-5015 Telephone: (303) 771-1700 Toll-free (800) STROKES (787-6537) | Promotes stroke prevention, treatment, rehabilitation, family support, and research. Provides:; - Educational books, pamphlets, and audiovisual materials about stroke for stroke survivors, families, and caregivers.; - Information on local stroke clubs and other self-help groups.; - Support for stroke research.; - Training programs about stroke for health care professionals.; - Be Stroke Smart newsletter for stroke survivors, families/caregivers, and health care professionals.
Rosalynn Carter Institute Georgia Southwestern College 600 Simmons Street Americus, GA 31709 | Provides information on caregiving. Reading lists, video products, and other caregiver resources are available by writing to the address listed at left.
Stroke Clubs International 805 12th Street Galveston, TX 77550 Telephone: (409) 762-1022 | Run by stroke survivors. Promotes hiring of people with disabilities. Provides lists of stroke clubs in each State.
The Well Spouse Foundation P.O. Box 801 New York, NY 10023 Telephone: (212) 724-7209 Toll-free (800) 838-0879 | Provides support for the husbands, wives, and partners of people who are chronically ill or disabled. Provides bimonthly newsletter, regional support groups, pen pal system, and an advocacy program.

## Safety and Health Promotion During Transition

### Fall Prevention

Recommendation: Fall prevention after the stroke survivor returns to a community residence should emphasize identifying patient, treatment, and environmental risk factors, and steps to reduce these risks. (Research evidence = C; expert opinion = strong consensus.)

The efforts of stroke survivors to increase mobility inevitably increase the risk of falls. The goal is to minimize these risks while encouraging efforts to achieve independence. Potentially remediable risk factors include residual muscle weakness, problems with balance or gait, problems with vision, orthostatic hypotension, overuse of sedatives, medication side effects, and inappropriate assistive devices or inadequate training in their use (Rubenstein, Robbins, Josephson, et al., 1990). Environmental hazards such as scatter rugs, elevated thresholds, unsafe placement of furniture, and inadequate lighting are also important.

Fall prevention may include exercise regimens that increase muscle strength and improve postural control, modification of medication regimens, careful attention to the selection and use of assistive devices and wheelchairs, and home modifications to reduce the risk of tripping and increase the ease with which a person can perform daily activities. Improved access to bathroom facilities will be particularly helpful in reducing the risk of falls. A well-designed fall prevention program has been shown to reduce falls by 9 percent, rehospitalization by 26 percent, and hospital days by 52 percent (Rubenstein, Robbins, Josephson, et al., 1990).

Injuries from falls and the fear of falling may both impede recovery. Fall prevention needs to aim at both physical and psychological outcomes. Teaching the stroke survivor and family members techniques for getting up after a fall can help reduce anxiety.

### Health Promotion

Recommendation: High priority should be given to the prevention of stroke recurrence and stroke complications and to health promotion more generally, after the stroke survivor returns to the community. (Research evidence = A; expert opinion = strong consensus.)

The risk of suffering a second stroke averages 7 to 10 percent per year, and the risk of complications remains high, especially in severely disabled people with limited mobility. Interventions to prevent stroke recurrence and complications of stroke such as urinary tract infections, aspiration, pressure ulcers, DVT, and pulmonary emboli were discussed in Chapter 4. Continued efforts to prevent recurrent strokes are essential. The choice of therapies will depend on the etiology of the stroke and the stroke survivor's risk-factor profile. Steps to control risk factors such as hypertension, tobacco use, diabetes mellitus, hyperlipidemia, and drug abuse should be pursued. Timely vaccinations to prevent influenza and pneumococcal infection are very important in older patients.

## Resuming Valued Activities

### Leisure and Recreational Activities

Recommendation: Valued leisure activities should be identified, encouraged, and enabled. (Research evidence = C; expert opinion = strong consensus.)

Participation in leisure activities is closely related to both health status and quality of life (Drummond, 1990; Jongbloed and Morgan, 1991; Krefting and Krefting, 1991; Shank, 1992; Sjogren, 1982). Emphasis on leisure activities during rehabilitation can reinforce treatments directed at physical, emotional, and cognitive impairments or disabilities (MacNeil and Pringnitz, 1982). After return home, interest in leisure and recreational activities may provide a strong motivation to resume an active lifestyle. The support of family members and friends should be mobilized to influence a person's self-appraisal, roles, and participation in leisure activities.

Several measures of leisure activities have been developed (Holbrook and Skilbeck, 1983; (Wade, Legh-Smith, and Langton-Hewer, 1985). Broadly, efforts to assess, encourage, and enable leisure and recreational activities after the stroke survivor returns home should include:

- Assessment of pre-stroke interests and activities.
- Agreement on short-term and longer-term goals.
- Review of valued activities against current functional levels.
- Evaluation of the suitability of current adaptive equipment.
- Development of strategies to overcome physical barriers in the home and community.
- Identification of new leisure activities to match functional abilities.
- Education concerning available community resources.
- When needed, advocacy for the development of community programs.

In addition to purely recreational activities, stroke survivors may be interested in opportunities for volunteer work. Volunteer activities not only can be rewarding in themselves, but also can provide a transition to paid employment for some people.

### Sexuality

Recommendation: Sexual issues should be discussed during rehabilitation and addressed again after transition to the community when the stroke survivor and significant other are ready. (Research evidence = NA; Expert opinion = strong consensus.)

Sexual issues relate both to sexual function and to changes in body image as a result of stroke. Sexual activity usually diminishes and sometimes ceases after stroke (Bray, DeFrank, and Wolfe, 1981; Coslett and Heilman, 1986; Kalliomaki, Markkanen, and Mustonen, 1961), but sex remains important to the majority of stroke survivors. Decreases in libido or the ability to achieve orgasm are common after stroke (Coslett and Heilman, 1986; Garlinghouse, 1987). Men may experience difficulty in achieving an erection or ejaculating due to neurological impairments or the effects of medications, most notably those used to treat hypertension and cardiac disease; and women may experience changes that cause them to feel equally impotent. Psychological factors, dependency in self-care activities, and changes in sexual roles each may be important.

Sexual issues are often not adequately addressed despite evidence that patients and their partners welcome frank discussions. The most important message is that sexual activity is not contraindicated after stroke. However, both parties need to recognize and adjust for the effects of motor, sensory, and attentional deficits, easy fatigability, changes in body image, and self-esteem. Interventions that stress the importance of effective communication, sharing of concerns, and development of adaptive strategies such as positioning, foreplay, and timing to avoid fatigue are often helpful (McCormick, Riffer, and Thompson, 1986; Sjogren, Damber, and Liliequist, 1983; Sjogren and Fugl-Meyer, 1982).

### Automobile Driving

Recommendation: Assessment of the ability of a disabled stroke survivor to drive a car should be based on a neurological examination, behavioral observations, and evaluation by the State agency responsible for issuing drivers' licenses (including a standardized driving test). Neuropsychological testing should be obtained in persons with cognitive or behavioral disorders. Referral to adaptive driving instruction should be considered. (Research evidence = C; expert opinion = consensus.)

More than half of stroke survivors who drove a car before their strokes stop driving afterwards (Legh-Smith, Wade, and Hewer, 1986). Factors that are most commonly associated with driving cessation are older age and the presence of cognitive deficits. The ability to resume driving promotes independence and can also help greatly to avoid a sense of isolation.

Studies have come to mixed conclusions about the relative merits of neuropsychological examinations and standardized driving tests in evaluating persons with disabilities who wish to resume driving. Some studies suggest that persons who pass tests for cognitive deficits (including visuospatial deficits) do not require a road test (Nouri, Tinson, and Lincoln, 1987; Sivak, Olsen, Kewman, et al., 1981). Other studies find that cognitive testing alone is insufficient and recommend that a standardized driving test be mandatory (Brooke, Questad, Patterson, et al., 1992; Katz, Golden, Butter, et al., 1990; van Zomeren, Brouwer, and Minderhoud, 1987).

The panel's recommendations reflect the fact that stroke survivors may be able to pass a driving test despite having visuospatial deficits or problems with easy distractibility, impulsive behaviors, or slowed decisionmaking that may impair their ability to drive safely under unpredictable road conditions. These problems will usually be detected during rehabilitation. If questions persist, however, a neuropsychological evaluation should be obtained prior to the driving test.

Decisions on a stroke survivor's ability to drive also need to take account of medical problems such as the control of seizures, and must satisfy local regulations that govern driving with an impairment or medical condition. Referral to an adaptive driving instruction program should be considered in appropriate patients. The only study that has examined the effectiveness of cognitive potential training concluded that training may improve perceptual skills and driving performance (Sivak, Hill, Henson, et al., 1984).

The final authority on whether a person is allowed to drive is the bureau or department of motor vehicles or other agency responsible in each State for issuing driver's licenses. The person who has had a stroke and wishes to resume driving should inform that agency and seek validation of his or her ability to drive safely. The person's insurance company should also be notified both about the stroke and about the subsequent validation of driving ability from the State agency.

### Returning to Work

Recommendation: Stroke survivors who worked prior to their strokes should, if their condition permits, be encouraged to be evaluated for the potential to return to work. Vocational counseling should be offered when appropriate. (Research evidence = NA; expert opinion = consensus.)

The ability of a person to pursue a vocation is an important determinant of the quality of life. This is as true for older people who would like to work as it is for younger people. The 1986 ICD Survey of Disabled Americans, in fact, stated that "not working is perhaps the truest definition of what it means to be disabled" (Louis Harris and Associates, 1986). The Americans with Disabilities Act of 1990 prohibits discrimination in employment against people with disabilities.

Vocational rehabilitation has been congressionally mandated for over 50 years to provide permanently disabled people with whatever assistance is necessary to prepare them for work that they can do successfully. However, a population survey published by the U.S. Census Bureau in 1988 revealed that only 32 percent of working-age adults with disabilities were working or actively seeking employment.

#### Barriers to Vocational Reintegration.

There are many barriers to successful vocational reintegration of individuals with disabilities from stroke. These include:

- Lack of knowledge about stroke and its consequences among stroke survivors, their families, communities, potential employers, and community-based social service and allied health professionals.
- Architectural barriers in the workplace.
- Limited access to appropriate vocational rehabilitation resources in communities distant from major rehabilitation facilities.
- Limited awareness of vocational services on the part of health professionals (Smolkin and Cohen, 1974).
- Negative attitudes of some health professionals toward return to work by stroke survivors (Smolkin and Cohen, 1974).
- Misunderstanding and negative attitudes on the part of stroke survivors and families toward vocational rehabilitation as a result of lack of information on the services available and how to obtain them.
- Depression or other emotional problems affecting the motivation and ability of a stroke survivor to seek employment.
- Financial disincentives in such areas as health insurance coverage, disability payments, and costs of environmental adaptions and transportation.
- Inefficiency or lack of interest of vocational rehabilitation programs in dealing with stroke survivors.

#### Major Needs for Vocational Rehabilitation

To serve stroke survivors effectively, the vocational rehabilitation system needs to improve assessment, interventions, patient education, and patient advocacy.

Traditional vocational assessment methodologies may close off opportunities for stroke survivors with behavioral or cognitive deficits and result in low-paying, unsatisfying jobs (Nadolsky, 1985). Flexible assessment and placement models are needed that take account of a variety of personal, medical, psychological, educational, work history, community, and economic variables--and are firmly rooted in real work and living situations. None of the evaluation tools available to help determine a person's readiness for vocational rehabilitation have been validated in patients with stroke. The better known tools include: a Vocational Assessment Protocol (VAP) (Thomas, 1990), Work Performance Assessment (WPA), McCarron-Dial Perceptual Memory Task (PMJ) (Chan, Lynch, Dial, et al., 1993), Work and the Supervisors Rating Scale and Functional Assessment Inventory (Crowe and Athelestan, 1981).

Vocational interventions traditionally follow the medical model that sequentially evaluates deficits, prescribes treatments to fix the problems, tests the solution within a prescribed range of job options, and recycles the client if the initial placement fails. Client-centered services would depart from this approach by eliciting the full partnership of the stroke survivor and family/caregiver from the beginning, and by retaining flexibility to change objectives and strategies as the person's capabilities grow or the work environment changes. The ability of the program to build skills and to offer retraining programs may be particularly important in helping the stroke survivor find employment.

The greatest opportunities for clinicians to support vocational reintegration are in the areas of education and advocacy. Clinicians should be prepared to assist persons who have been disabled by strokes and wish to examine the possibility of returning to work. They should make sure that these people are given complete information on available vocational rehabilitation programs, are helped in gaining access to these, and receive an assessment of their potential to return to work that takes into account prior employment, present physical condition, psychological and social status, and motivation.

In addition, both clinicians and vocational rehabilitation professionals should talk with employers to encourage them to hire people with disabilities from stroke or other causes. Myths about negative effects of disabilities on work productivity need to be dispelled. Vocational rehabilitation professionals should provide technical assistance to employers in conducting job analyses, writing job descriptions, and providing job accommodations that are appropriate to employees who have had strokes.