# Managing Rehabilitation

## Introduction

This chapter describes the principles and processes of rehabilitation for patients who are admitted to an interdisciplinary program in any type of setting: inpatient hospital rehabilitation facilities, nursing facilities, outpatient or day hospital facilities, and home-based programs. The complexity, intensity, and duration of services vary among settings, but the principles and processes are similar. The focus is on the patient who enters a rehabilitation program following an acute hospitalization for stroke. It is recognized that many patients will require a continuum of care involving movement from one level to another as recovery proceeds. These transitions often reflect a cost-effective use of rehabilitation resources. The present discussion establishes a framework for the initial rehabilitation program, but many of the same considerations apply to later stages and to people with mild deficits who receive rehabilitation services from a single provider.

Preventing complications of stroke is just as important during rehabilitation as it is during the acute hospitalization. The reader is referred to Chapter 4 for a discussion of preventing complications.

## Principles of Rehabilitation

Rehabilitation seeks to help the person with disabilities achieve the highest possible degree of physical and psychological performance. To these ends, rehabilitation is both a philosophy and a set of tasks; a rehabilitation program is comparable to school in which the patient is provided an opportunity for instruction, support, protected practice, education, reassurance, direct assistance, and feedback. Rehabilitation has been aptly described as "the planned withdrawal of support," in which services are provided when needed and removed when no longer needed (Roth, 1988). Intrinsic features are involvement of the patient and family in setting goals and planning and implementing treatments, and systematic withdrawal of assistance and return of control to the patient (Charness, 1986; Hyams, 1969). Rehabilitation is done with the patient rather than to the patient.

Brandstater and Basmajian (1987) and Roth (1988) identify the following common features of comprehensive stroke rehabilitation programs:

- Commitment to continuity of care from the acute phase of the stroke through long-term followup.
- Use of an interdisciplinary team of professionals experienced in and dedicated to the care of the patient with stroke.
- Careful attention to the prevention, recognition, and treatment of comorbid illnesses and intercurrent medical complications.
- Early initiation of goal-directed treatment that takes maximal advantage of the patient's abilities and minimizes disabilities.
- Emphasis on skills development and functional enhancement through training, demonstration, supervision, practice, and appropriate feedback.
- Systematic assessment of the patient's progress during rehabilitation, with adjustment of treatment to maximize benefits.
- Emphasis on patient and family/caregiver education.
- Attention to psychological and social issues affecting both the patient and family/caregiver.
- Early and comprehensive discharge planning aimed at a smooth transition to the community, and at continuity of care to promote social reintegration and resumption of roles in the home, family, recreational, and vocational domains.

Rehabilitation treatments aim to reduce impairments (remediation) or to help patients relearn old skills or develop new ones despite persisting neurological deficits (compensation). Patient and family education, emotional support, psychological counseling, recreational therapy, vocational counseling, and orthotics may also make important contributions. Throughout rehabilitation, attention needs to be directed to the carryover of skills that are learned to different settings. For example, skills learned in an ideal rehabilitation environment often have to be adapted to circumstances existing in a permanent place of residence.

## Transition From the Acute Care Hospital

The challenges faced by the patient and family depend on whether the patient returns home to receive rehabilitation there or in an outpatient facility or is transferred to an inpatient rehabilitation hospital or nursing facility for rehabilitation. In either case, adjustment may be difficult.

A return to a familiar environment has distinct advantages, but it also involves a marked reduction of professional support and requires the patient and family to assume responsibility for daily functions and continued recovery. Most outpatient or home rehabilitation programs are limited to a few hours 3 or 4 days a week and are of fairly low intensity. Exceptions are the intense day hospital or home rehabilitation programs that are available in some communities. Chapter 7 discusses the issues that arise during the transition to community living.

Transfer to an inpatient or nursing facility rehabilitation program can also be difficult. These settings offer the advantage of more professional support, as well as support from other patients, which often helps to reduce anxiety and strengthen motivation. However, the people, environment, and procedures encountered in rehabilitation settings are very different from those of the acute hospital and may be confusing at first. Prompt and thorough orientation of patients and families, sensitivity to their concerns, and ample time devoted to addressing questions facilitate adjustment. Rehabilitation is a learning experience that works best when the patient is at ease, the environment is conductive to learning, and the training is focused.

Recommendation: A complete record of medical information from the acute care hospital should be available at the time of admission to any type of rehabilitation program. Significant discrepancies between these records and current clinical findings should be identified and addressed immediately. (Research evidence = NA; expert opinion = strong consensus.)

Transfer to any type of rehabilitation setting requires the prompt transfer of complete medical information including the discharge summary from the acute hospital, results of the rehabilitation screening examination, and current medications. This information should accompany the patient or be sent in advance. Rehabilitation staff should review these records on the day of admission to detect any new problems, significant discrepancies in clinical findings, or urgent questions about treatment regimens. Patients with a stroke usually have medical problems in addition to stroke, and even those who were considered medically stable at the time of transfer are at risk of untoward changes in their condition.

## Managing the Rehabilitation Process

A well-conceived rehabilitation management plan is the foundation of a rehabilitation program. This should reflect the priorities expressed by the patient and family, should be based on the results onf a baseline clinical assessment of medical conditions and neurological deficits, and should be consistent with the capabilities of the particular rehabilitation setting. The rehabilitation plan includes a clear description of the patient's impairments, disabilities, and strengths; explicit statements of short-term and long-term functional goals; and specification of treatment strategies to achieve the goals. Priorities need to be clearly established among goals, especially in patients with multiple complex deficits.

A schematic diagram of the steps in developing the rehabilitation management plan is shown in Figure 6. Monitoring progress and reevaluating treatment goals and strategies are essential features.

Development of a rehabilitation management plan

### Baseline Assessment on Admission to a Rehabilitation Program

#### Timing and Content

Recommendation: A complete baseline assessment by the rehabilitation team should be completed for most patients within 3 working days after admission to an intense rehabilitation program in an inpatient rehabilitation facility or nursing facility, within 1 week of admission to a low-intensity nursing facility program, or within three visits for an outpatient or home rehabilitation program. Initial evaluation by a physician and a nurse, including medical and neurological examinations and development of a medical care plan, should be completed within 24 hours of admission or, in the case of outpatient and home programs, on the first visit. All information should be fully documented in the patient's record. (Research evidence = NA; expert opinion = consensus.)

The baseline assessment reaffirms the referral decision, provides the information needed to develop rehabilitation goals and a management plan, and serves as the starting point for monitoring progress. The recommended content is summarized in Table 12.

Table 12. Baseline assessment on admission to a rehabilitation program

- Historical information; - Discharge summary from acute hospitalization.; - Complete profile from screening examination.; - General clinical assessment: neurological and medical examinations and; - selected laboratory tests; - Type(s) and severity of neurological deficits.; - Type(s) and severity of comorbid diseases.; - Complications of stroke.; - Functional health patterns: nutrition and hydration, ability to swallow, bowel and bladder function, skin integrity, activity tolerance, sleep patterns.; - Functional status prior to stroke.; - Social and environmental factors; - Presence of spouse or significant other.; - Previous living situation.; - Ethnicity and native language.; - Adjustment of patient and family to stroke.; - Patient and family preferences for and expectations of rehabilitation.; - Extent of support by family or involved others (relationships, number, health, availability).; - Characteristics of potential postdischarge environments.; - Standardized instruments; - Stroke deficit scale and mental status screening if not done as part of the screening examination.; - Impairment measures (individualized to patient's deficits):; - Motor function.; - Mobility.; - Balance.; - Language and speech.; - Measure of disability (ADL).; - Family assessment.

Note: ADL = activities of daily living.

Evaluation by a physician and a nurse on the day of admission to an inpatient rehabilitation program is essential to determine the patient's current clinical status, identify current medications, assess ability to perform basic ADL (such as feeding, toileting, and transfers), observe behavioral patterns, and identify safety risks. Home and outpatient rehabilitation programs should perform this initial evaluation during the first visit. Any discrepancies with the acute hospital's records should be noted and resolved as soon as possible. A thorough medical history, medical and neurological examinations, and evaluation of functional health patterns provide the foundation. Particular attention should be paid to detecting signs of incipient complications such as DVT, recurrent stroke, or skin breakdown.

The use of standardized instruments facilitates reliable documentation of functional disabilities. This helps to increase the consistency of treatment decisions, facilitates communication among therapists, and provides a reliable basis for monitoring progress. A stroke deficit scale and a mental status screening test need not be repeated if they were administered during a recent rehabilitation screening examination, unless findings of the neurological examination suggest changes in levels of impairment. A broad-based disability scale should be used with all patients. The choice of specific impairment measures will depend on the deficits of the individual patient.

The 3-day, 1-week, or three-visit limit for completing the baseline assessment reflects both cost and quality of care considerations. These limits, though somewhat shorter than the norm of current practice, are reasonable for all except the most complex patients. People with multiple deficits in sensorimotor, cognitive, perceptual, language, and behavioral areas may require longer periods of evaluation.

#### Evaluating Disabilities

Recommendation: A well-standardized measure of disabilities in basic ADL should be administered to all patients by a rehabilitation professional who is skilled in its use. (Research evidence = NA; expert opinion = strong consensus.)

The primary goal of rehabilitation is to improve functional capability of patients. The two instruments described in Attachment 4 are the most widely used and best validated of those available.

#### Evaluating Motor Function

Recommendation: Baseline assessment of motor function should include thorough evaluation of motor control and muscle strength, mobility, balance, and coordination (using standardized instruments). Assessment should be performed by professionals who are experienced in rehabilitation and the evaluation of neurological impairments and the completion of these instruments. (Research evidence = NA; expert opinion = strong consensus.)

Complete, accurate, and reliable documentation of motor impairments is essential to successful rehabilitation. The recommendation stresses the major ingredients. Impairments should be documented using standardized instruments such as those described in Attachments 6, 7, and 8.

#### Evaluating Cognitive Function

Recommendation: A clinical psychological examination should be performed in patients who show evidence of cognitive or emotional problems on clinical examination or a mental status screening test. Complete neuropsychological testing is required when more precise understanding of deficits will facilitate treatment. (Research evidence = NA; expert opinion = consensus.)

The incidence of cognitive deficits and emotional disorders in stroke patients is high (Hibbard and Gordon, 1992) Schubert, Taylor, Lee, et al., 1992d). Cognitive deficits are often associated with longer lengths of stay in rehabilitation programs and with poorer functional outcomes (Galski, Bruno, Zorowitz, et al., 1993; Hier and Edelstein, 1991; Jongbloed, 1986).

A clinical psychological evaluation should sample key cognitive, emotional, behavioral, and motivational domains. Cognitive elements include attention, orientation, memory, language, reasoning, judgment, spatial skills, motor coordination, and social skills. By far, the most common emotional disturbance after a stroke is depression (see Chapter 6). Motivation refers to awareness of deficits and their consequences, attitudes toward rehabilitation, and the level of energy that a patient is able and willing to commit.

A typical examination will require 1 to 2 hours by a mental health professional. Goals are to obtain a profile of the patient's strengths and weaknesses and to identify areas that require attention during rehabilitation or further neuropsychological testing. A neuropsychological examination may be helpful in determining the location of specific brain damage and its implications for treatment. This guideline leaves the selection of instruments or batteries to the discretion of the neuropsychologist.

#### Evaluating Communicative Function

Recommendation: Patients with problems in functional communication on routine testing should be evaluated using a motor-speech examination, a functional assessment of language and communication abilities, and selected standardized tests. Assessment should be performed by a professional who is experienced in the evaluation of speech and language disorders and in the administration of these instruments. (Research evidence = NA; expert opinion = consensus.)

Speech and language disorders may significantly interfere with the patient's ability to participate in rehabilitation or to return to an independent and fulfilling life. A thorough and accurate assessment of underlying deficits is essential to effective treatment planning. Suggested standardized instruments are listed in Attachment 9.

#### Evaluating Family/Caregiver Support and the Living Environment

Recommendation: Assessment of family and potential caregiver support and of the living environment is an important part of baseline assessment. A well-standardized instrument should be used when applicable. (Research evidence = NA; expert opinion = strong consensus.)

The patient's support system and contextual factors concerning the patient, family or involved others, and potential living environments (see Table 6 and Attachment 12) should be evaluated at the time of admission to rehabilitation and again before discharge. Rehabilitation requires full knowledge of the personal and physical environments in which the patient will be functioning. Use of an instrument, such as the Family Assessment Device, is recommended with patients who have families (spouse or other). This instrument has been used extensively with stroke patients and has a well-demonstrated ability to identify family characteristics relating to problem solving, roles, communication, affect, behavior control, and general functioning.

### Setting Rehabilitation Goals

Recommendation: Both short-term and longer term goals need to be realistic in terms of current levels of disability and the potential for recovery. Goals should be mutually agreed to by the patient, family, and rehabilitation team and should be documented in the medical record in explicit, measurable terms. (Research evidence = NA; expert opinion = strong consensus.)

Overly ambitious goals for rehabilitation will set the patient (and family) up for failure and may lead to unwarranted use of rehabilitation facilities. However, goals that are too modest may not make full use of the patient's potential.

Four considerations are especially important. First, recovery after stroke is highly variable and only partly predictable. Even carefully conceived goals may be inaccurate. For this reason, goals that are set at the time of admission to a rehabilitation program need to be reevaluated at regular intervals and modified to reflect the rate of a patient's progress.

Second, the time since stroke onset is important. Recovery due to neurological healing is most rapid during the first 1 to 3 months after a stroke and then plateaus. Significant functional improvement is less common after 6 months, although it can occur (Kelly-Hayes, Wolf, Kase, et al., 1989; Skilbeck, Wade, Hewer, et al., 1983). Expectations for further improvement might therefore be more optimistic in a patient with a recent stroke and a favorable initial recovery trajectory--than in a patient whose stroke occurred 2 or 3 months before--or one who has improved little during the post-stroke period.

Third, rehabilitation goals need to take into account patient characteristics that have been associated with poor functional prognoses (see Chapter 2). For example, persistent urinary incontinence often portends a poor outcome. The absence of any volitional movement in a limb 2 to 4 weeks after a stroke suggests that significant neurological recovery is unlikely, and that rehabilitation goals might better be focused on training in compensatory techniques, or the use of adaptive equipment.

Finally, rehabilitation goals need to address the full range of factors that influence functional performance, including psychological and social adjustment and physical conditioning.

### Developing the Rehabilitation Management Plan

Recommendation: The rehabilitation management plan should indicate the specific treatments planned and their sequence, intensity, frequency, and expected duration. Measures to prevent complications of stroke and recurrent strokes should be continued. (Research evidence = NA except for some preventive measures; expert opinion = strong consensus.)

As a general principle, medical problems or complications of stroke that increase patient risk or interfere with rehabilitation should be addressed first. Examples include congestive heart failure, urinary tract infections, and musculoskeletal pain. High priority is also given to the prevention of thromboembolism and recurrent stroke (as discussed in Chapter 4), and the maintenance of functional health patterns such as nutrition and bowel and bladder control.

Rehabilitation therapies then target impairments in mobility and motor control and disabilities in ADL performance. Treatments for depression or other emotional problems, perceptual deficits, and speech and language problems are added in patients who need them.

Decisions on the intensity and frequency of interventions depend heavily on the patient's physical endurance, level of motivation, and attention span. The patient's ability to tolerate physical activity will often be limited by preexisting health problems, age-related physiologic changes, or deconditioning effects of immobility (Mol and Baker, 1991). As discussed in Chapter 3, there is currently no standard approach to evaluating physical activity endurance. Patients with severe limitations in exercise tolerance may be best served by a slowly paced program or even by delaying rehabilitation until after a further period of recuperation.

The patient's motivation to participate in rehabilitation is also an important consideration. Assessment of motivation is complex and imprecise. Apparent motivational problems may actually reflect communication deficits or lack of clarity in instructions by staff. Poor motivation may be due to modifiable causes such as depression, incongruence between the patient's goals and those of the rehabilitation program, or a failure of the rehabilitation team to make clear the connection between interventions and goals that are valued by the patient. Motivation may also be affected by neurological deficits that lead to hypoarousal, apathy, or a lack of awareness of disabilities. Mood or memory disorders are especially likely to be denied by patients (Anderson and Tranel, 1989; Hibbard, Gordon, Stein, et al., 1992).

The family may play a pivotal role in helping to identify depressive symptoms or areas of misunderstanding or dissatisfaction with the rehabilitation program and may also help the patient cope with the effects of the stroke and develop the motivation to make a maximal effort to recover (Phipps, 1990). If, despite all efforts, the patient is not able to participate actively, rehabilitation may have to be deferred.

### The Interdisciplinary Team Approach

The varied and complex manifestations of stroke often require the services of specialists from several disciplines. The team approach facilitates coordination of care; simultaneous treatment of motor, cognitive, and speech and language deficits; and tailoring of treatment schedules to the patient's priorities and responses to treatment.

Composition of the team varies with the patient's needs and the available resources. In comprehensive inpatient programs, participants include a physician expert in rehabilitation, a rehabilitation nurse, a physical therapist, an occupational therapist, a clinical psychologist, a social worker, and often a therapeutic recreation specialist. A speech-language pathologist will often become involved if the patient has speech, language, or swallowing problems. Other participants may include a psychiatrist, other medical or surgical specialists, and a physician assistant, respiratory therapist, registered dietitian, vocational counselor, chaplain, orthotist, or rehabilitation engineer.

Effective teamwork is not easy. Conflicts arise when communication breaks down or when differences of opinions or interpretations of the patient's behavior are not resolved (Rothberg, 1981). Strong leadership, clarity of roles and responsibilities, and a willingness to devote time and effort to communication are essential. The team leader, who may be from any discipline, is the central figure and assumes primary responsibility for coordinating services and facilitating communication among team members, the patient, and the family. Team conferences, frequent contacts among team members, and complete and intelligible entries in the patient's medical record are important.

The conceptual appeal of the team approach for coordinating stroke care has led to its widespread adoption. However, concrete evidence supporting its effectiveness and cost effectiveness is limited. A literature review concluded that team care resulted in better control or less deterioration in patients with chronic illnesses--but also in more utilization of health services and higher costs (Halstead, 1976). Controlled studies of team care in stroke rehabilitation are limited to the previously discussed (see Chapter 4) stroke unit studies, in which the "team" is one aspect of a multidimensional intervention. Ultimately, the greater expense of the team approach needs to be justified by documentation of greater patient benefits.

### Implementation Principles

#### The Learning Process

Recommendation: Rehabilitation should follow well-supported principles of effective learning. (Research evidence = C; expert opinion = strong consensus.)

Rehabilitation is predominantly a learning process. Adherence to basic principles of learning requires that:

- Careful assessment is done to determine tasks that a patient can perform.
- The skills or knowledge being taught are meaningful to the patient.
- Training is graded by level of difficulty, and less complex or demanding tasks are addressed first, so that the patients can experience success.
- Instructions are phrased as concretely as possible and are short, direct, and simple.
- Instructions are understood.
- Tasks to be mastered or information to be learned are tailored to the person's abilities in order to avoid "overload."
- Steps are taken to slow patient responses if impulsivity causes a person to perform a task too rapidly or unsafely.
- Feedback on performance is provided by the therapist or by use of videotapes to reinforce desired responses.
- Steps are taken to stimulate responses (e.g., by timing the patient in the performance of a task or by talking about favorite activities) in order to overcome periods of hypoarousal or lethargy.
- Repetition and practice are used between training sessions when the patient is on the unit or at home.

Application of these principles should take account of the patient's current abilities and should be adjusted in response to improvements over the course of rehabilitation.

#### Family Involvement

Recommendation: Families or involved others should be active participants in the rehabilitation process. (Research evidence = NA; expert opinion = strong consensus.)

Family involvement in the rehabilitation process includes encouraging the free expression of questions, concerns, and ideas; participation in the development of rehabilitation goals and the management plan; the opportunity to validate expectations of rehabilitation against the realities of patient progress; and "hands-on" participation in therapy sessions. The family can, and should, serve as an active advocate for the patient throughout the rehabilitation process. Easy access to information will help allay the family's anxieties and build a partnership toward understanding and confronting the patient's disabilities. Active participation of family members in therapy sessions provides encouragement to the patient at the same time as it helps to develop the skills needed to assist the patient at home.

#### Patient and Family Education

Recommendation: Patients, families, and involved others should be given information and provided with ample opportunity to learn about the causes and consequences of stroke and the goals, process, and prognosis of rehabilitation. Family members and other potential caregivers should receive thorough training in techniques and problem-solving approaches required to provide effective support. (Research evidence = B; expert opinion = strong consensus.)

Patient and family education is an integral part of rehabilitation. It greatly contributes to achieving improved outcomes (Evans, Matlock, Bishop, et al., 1988). Education begun during the acute hospitalization is reinforced early and often during rehabilitation through discussions among the patient, family, and therapists; didactic sessions; family participation in therapy sessions; and the use of books, brochures, and videotapes. Potential topics are listed in Table 13.

Table 13. Issues for patient and family/caregiver education

What is stroke?; - Etiology of stroke.; - Effects of stroke on the patient.; - Effects of stroke on the family.
Routine care in the hospital, rehabilitation setting, or home; - Maintenance of nutrition and hydration.; - Bowel and bladder care.; - Sleep and rest.; - Reliable medication taking.; - Behavioral issues and how to deal with them.; - Positioning and moving in bed.; - Prevention of blood clots.; - Prevention of skin breakdown.; - Safety measures to prevent falls.; - Exercise during and after rehabilitation.; - Techniques for performing specific tasks, such as transfers, personal hygiene, etc.; - Training in specific skills for which patient needs assistance.; - Optimizing social functioning.
Complications of stroke (tailored to patient's specific circumstances); - Swallowing problems.; - Care/use of indwelling bladder catheter or feeding tube.; - Respiratory complications.; - Care of tracheostomy/use of respiratory equipment.; - Speech or language deficits; facilitating communication.; - Depression and other psychological disturbances.
Prevention of recurrent stroke; - Monitoring blood pressure.; - Medical or surgical interventions to prevent recurrent stroke.; - Lifestyle modification.
After hospital care; - Caregiver concerns.; - Family functioning.; - Support groups, respite care.; - Sexual functioning.; - Recreational and vocational pursuits.; - Automobile driving.; - Vocational counseling.

Education should be adapted to the educational and cultural background of the patient and family, the mental status of the patient, and emotional factors that may interfere with learning. Experiential learning is often more effective than didactic learning, and repetition is important.

#### Counseling and Psychotherapy

For the purposes of this guideline, counseling is defined as supportive and educational interventions to assist the patient or family in identifying key issues and problem solving around them. Psychotherapy is defined as interventions to change basic mental functions in a person or organizational or transactional patterns in families. Counseling can be provided by a variety of rehabilitation professionals, but psychotherapy is limited to psychiatrists, psychologists, social workers, and psychiatric clinical nurse specialists. Since a recommendation for psychological or social help may be interpreted by patients or their families as an indication that they are somehow deficient, careful assessment and a thorough understanding of the underlying issues should always precede such recommendations. A decision to recommend counseling or psychotherapy should be made only after discussion with the rehabilitation team. Patients and families are able to resolve many problems on their own, without formal counseling, after the problems have been identified and treatment options have been discussed.

### Monitoring Progress During Rehabilitation

Recommendation: The patient's progress during rehabilitation should be documented at least weekly during an intense rehabilitation program in an inpatient rehabilitation facility or nursing facility, and at least every other week during less intense nursing facility, outpatient, or home programs. A subset of the standardized measures administered at baseline assessment should be chosen, targeting those impairments and disabilities that have been the focus of treatments during the preceding period. (Research evidence = NA; expert opinion = strong consensus.)

Regular evaluation of progress is needed to obtain the information required to adjust treatment regimens and also to justify continued rehabilitation. Under most circumstances, it is reasonable to expect that measurable (and meaningful) improvement will occur over 1 week during an intense program or over 1 month during a less intense program. An exception would be if rehabilitation were interrupted by an acute illness or for other reasons.

Assessment should include both a clinical examination and a subset of the standardized instruments used during the baseline assessment (see Table 12). Emphasis should be on areas of impairment or function that have been particular targets of interventions during the preceding period. The use of well- standardized, reliable measures is essential to achieving valid comparisons from examination to examination and also comparisons among patients with similar problems. Clinical examinations document changes in medical conditions and areas of progress not addressed by the standardized measures. Regular discussions with family/caregivers can also provide important information on the patient's progress.

Changes in regimens may address specific medical, emotional, or cognitive problems that are impeding physical rehabilitation or may modify the type or intensity of specific treatments or educational interventions.

## Preventing Recurrent Stroke and Deep Vein Thrombosis

Prevention of recurrent stroke and prevention of deep vein thrombosis are discussed for the acute care setting in Chapter 4. The same measures continue to apply throughout rehabilitation.

## Managing Comorbidities and Acute Illnesses

### Associated Medical Conditions

Most patients with strokes have other medical conditions that require treatment during rehabilitation. Severe illnesses may limit the patient's ability to participate in therapeutic exercise and reduce the likelihood of favorable rehabilitation outcomes (Lehmann, DeLateur, Fowler, et al., 1975; Roth, Mueller, and Green, 1988). Common diseases are hypertension, ischemic heart disease, congestive heart failure, chronic pulmonary disease, and diabetes mellitus. Goals of treatment include adjusting antihypertensive medications to control blood pressure while avoiding postural (orthostatic) hypotension, treating angina pectoris and congestive heart failure with medications while adjusting exercise to the patient's abilities, and adjusting diet and medications (insulin, oral agents) in diabetics to accommodate changes in blood sugar that may occur during increased physical activity. A full discussion of the management of these and other comorbidities is beyond the scope of this guideline.

### Acute Illnesses

Recommendation: A patient who develops an acute medical illness during rehabilitation should be evaluated promptly and, if necessary, transferred to an acute care facility. (Research evidence = NA; expert opinion = strong consensus.)

Few rehabilitation programs have adequate diagnostic or treatment capabilities to care for acute medical illnesses such as acute myocardial infarction, pulmonary embolus, or gastrointestinal bleeding. These patients will require transfer to an acute care facility. Close cross-coverage arrangements with an acute care facility will, in some cases, reduce the need for transfer. The ability of rehabilitation facilities to care for other acute (but less life-threatening) illnesses such as urinary tract infection, pneumonia, or thrombophlebitis, varies widely. Decisions on the need for transfer should be individualized to the capabilities of the program. In general, rehabilitation programs should have a low threshold for obtaining consultations or initiating transfer when acute problems arise.

## Managing Functional Health Patterns

### Managing Dysphagia

The assessment of swallowing disorders (dysphagia) is discussed in Chapter 3, and management is discussed in Chapter 4. Swallowing problems frequently resolve spontaneously; however, the condition should be reassessed at the time of admission to rehabilitation and treatments continued or modified, if necessary.

### Maintaining Nutrition and Hydration

Recommendation: The adequacy of the oral intake of food and fluids should be monitored regularly. (Research evidence = NA; expert opinion = strong consensus.)

A significant number of patients have evidence of dehydration or inadequate nutrition at the time of admission with a stroke, and one report indicates that as many as 22 percent of patients evidence deficiencies by the time of discharge (Axelsson, Asplund, Norberg, et al., 1988). Possible causes of inadequate oral intake are dysphagia, an inability to chew or feed oneself, lack of interest in food, cognitive deficits such as inability to recognize hunger or thirst, and inability to make hunger or thirst known because of problems with communication. Possible effects are generalized weakness, increased risk of skin breakdown and pressure ulcers, electrolyte imbalance, and reduced ability to participate in rehabilitation.

To reduce the risk of malnutrition or dehydration, food and fluid intake should be monitored daily in all patients, and body weight should be determined regularly. Opportunities to improve intake include catering to a patient's food preferences, arranging for company during meals, providing assistance in feeding or otherwise encouraging intake, and treating specific problems that interfere with intake. If such measures are unsuccessful, feeding by a feeding gastrostomy may be necessary.

### Managing Bladder Function

Recommendation: Persistent urinary incontinence after a stroke should be evaluated to determine its etiology, and cause-specific treatment should be implemented. (Research evidence = C; expert opinion = strong consensus.)

Urinary incontinence that persists after a stroke is often associated with severe motor, proprioceptive, and visual deficits and a poor long-term prognosis (Reding, Winter, Hochrein, et al., 1987). Causes include damage to neural centers that govern bladder function, immobility that prevents timely access to toileting facilities, cognitive deficits that prevent recognition of the need to void, and communication problems that interfere with making needs known to others. Fecal impaction may also predispose to incontinence by causing pressure on the bladder. Potential complications include urinary tract infection, skin breakdown, social embarrassment, depression, and the need for institutionalization.

Documentation of the duration and pattern of urinary incontinence should include frequency of urination, timing, amount, whether voiding was preceded by the urge to urinate, discomfort on voiding (dysuria), and fluid intake patterns.

Management is cause-specific. In most cases, efforts should be made to remove an indwelling catheter, if one has been placed, in conjunction with a bladder training program that includes timed voiding and use of a commode or toilet instead of a bedpan. Intermittent catheterization may be indicated if postvoid residual volumes (PVR) greater than 50 cc are associated with symptomatic urinary tract infections. However, many patients tolerate increased PVRs without developing urinary tract infections and do not require intermittent catheterization. Bladder training is especially useful in patients who are alert and cooperative but may also be helpful in the cognitively impaired patient (Engel, Burgio, McCormick, et al., 1990; McCormick, Scheve, and Leahy, 1988; Schnelle, 1990). A clamping regimen prior to removal of an indwelling catheter does not appear to be helpful (Gross, 1990). Attention by staff to voiding needs and adequate access to toileting facilities are both essential.

Patient and family education in the management of bladder function is an important part of discharge planning.

### Managing Bowel Function

Recommendation: Bowel management programs should be implemented in patients with persistent constipation or bowel incontinence. (Research evidence = B; expert opinion = consensus.)

Fecal incontinence occurs in a substantial proportion of patients after a stroke but clears within 2 weeks in the majority (Brocklehurst, Andrews, Richards, et al., 1985). Continued fecal incontinence signals a poor prognosis. Diarrhea, when it occurs, may be due to medications, initiation of tube feedings, or infection. It can also be due to leakage around a fecal impaction. Treatment should be cause-specific.

Constipation and fecal impaction are more common after stroke than incontinence. Immobility and inactivity, inadequate fluid or food intake, depression or anxiety, a neurogenic bowel or the inability to perceive bowel signals, lack of transfer ability, and cognitive deficits may each contribute. Goals of management are to ensure adequate intake of fluid, bulk, and fiber and to help the patient establish a regular toileting schedule. Bowel training is more effective if the schedule is consistent with the patient's previous bowel habits (Venn, Taft, Carpentier, et al., 1992). Stool softeners and judicious use of laxatives may be helpful.

### Managing Sleep Disturbances

Recommendation: Sleep disturbances should be assessed and indicated changes for sleep habits, environment, or medications should be implemented as necessary. (Research evidence = NA; expert opinion = strong consensus.)

Sleep patterns may be altered by the effects of the stroke or by routines of a hospital or nursing facility. Inverted sleep-wake rhythms with lethargy during daytime hours and agitation at night, sleep apnea (Culebras, 1992), and reduced sleep efficiency with a suppression of REM sleep and increased non-REM sleep (Korner, Flooh, Reinhart, et al., 1986) have been reported to result from hemisphere strokes. Depression or anxiety may interfere with sleep (Chenelly, 1989). Muscle spasms, pain, inability to move in bed, and urinary frequency or incontinence can interrupt sleep. The unfamiliar environment of a hospital, noise, and awakenings for medications or vital signs also create problems for some patients (Beyerman, 1987).

Lack of adequate sleep can interfere with a patient's ability to participate in an intense rehabilitation schedule. Daytime rest periods may be needed because of fatigue due to vigorous activities, but these must be weighed against the ability of the patient to sleep at night.

Assessment of sleep problems includes the patient's sleep history, observation of sleep and waking behaviors, evaluation of medications, and examination of environmental factors. Management should address the cause of the sleep problem and treat the appropriate disability or symptom; change the environment to reduce disturbances during sleep or adjust the type, timing, and dose of the offending medication. Hypnotics should be used only if all else fails. In this regard, a small controlled trial found that flurazepam produced more daytime sedation than triazolam in patients with strokes (Woo, Proulx, and Greenblatt, 1991).

If sleep medications are used, side effects such as daytime sedation, paradoxical agitation, confusion, or memory problems need to be carefully monitored. Moreover, there is suggestive evidence that agents such as benzodiazepines may slow sensorimotor recovery (Goldstein, 1993), and these agents should be used only if all else fails. Interventions to keep the patient active and minimize daytime sleep, relaxation and other behavioral techniques to help induce sleep, and devices to prevent sleep apnea should also be considered.

## Managing Sensorimotor Deficits and Impaired Mobility

### Introduction

Sensorimotor deficits and restricted physical mobility are common after stroke. These problems may be complex in their own right and are made even more so by coexisting cardiovascular disease, arthritis, or physical deconditioning. A patient's movement problems may involve muscle weakness, abnormal synergistic organization of movements, altered temporal sequencing of muscle contractions, impaired regulation of force control, delayed responses, abnormal muscle tone, loss of range of motion, altered biomechanical alignment, and sensory impairments.

The first challenge facing a therapist is to determine which factors are contributing to movement or functional deficits. Assessment begins by observing a patient's attempts to accomplish functional tasks. Apparent disabilities are then examined using standardized measures of deficits in movement, posture, and physical performance. Thorough knowledge of the cause of impaired motor performance is needed to select appropriate exercises, treatment modalities, and activities.

The three philosophies that guide treatment choices for sensorimotor deficits are remediation or facilitation, compensation, and motor control (Duncan, 1992). The remediational approach is exemplified by traditional physical therapy exercises and neuromuscular facilitation. This approach uses forced sensory stimulation modalities, exercises, and resistive training to enhance motor recovery. Some degree of volitional movement in the involved limb is required.

In the compensatory model, the therapist emphasizes achieving independence in basic activities of daily living by attempting to improve function rather than enhancing motor recovery or minimizing impairments. Some therapists avoid the compensatory approach for fear that reliance on the noninvolved side to accomplish daily tasks will suppress recovery and contribute to learned nonuse of the impaired side ). Evidence supporting this conclusion is provided by studies showing that forced use of the impaired limb improves motor control in some patients (Taub, Miller, Novack, et al., 1993; (Wolf, Lecraw, Barton, et al., 1989). However, the compensatory strategy may be the only way to improve function after motor recovery has plateaued. Moreover, it may be preferred in patients with severe motor deficits who have a poor prognosis for recovery of sensorimotor function.

The third model is relatively new and incorporates theories of motor control and motor learning (Carr and Shepherd, 1989; Gordon, 1987; Winstein, 1987). Major tenets of this approach are that motor control represents a complex interaction of the neurological and musculoskeletal systems and the environment to enhance performance. This theory holds that motor control is task-specific, and hence, if one practices under one condition, the effects do not necessarily carry over to another condition. This concept is appealing, but evidence is lacking to support the superiority of treatments based on this view of motor control.

A myriad of therapeutic intervention strategies have been applied in attempts to improve motor control and physical performance. Table 14 provides examples of treatments for different types of impairment. As exemplified by the controlled studies summarized in Table 15, no one type of physical therapy has been shown to be superior to others. Since neuromuscular facilitation treatments are more labor intensive and more expensive than traditional physical therapy, objective proof of their greater effectiveness would be needed to justify their use.

Table 14. Examples of therapies for sensorimotor deficits and physical mobility

Impairments | Treatments
Sensory deficits | - Teach compensatory strategies.; - Patient accommodates to diminished sensory input during movement and functional activities.
Range of motion | - Passive and active range of motion.; - Joint mobilization.; - Splinting or casting.
Pain | - Positioning (e.g., slings, wheelchair tray, arm supports).; - Reduction of edema (elevation, pressure gloves or stockings, continuous passive motion, etc.).; - Modalities (ice, heat, ultrasound, etc.).; - Proper range of motion (techniques and sequence of exercises to avoid shoulder impingement syndrome).
Force control-voluntary control | - Facilitory modalities as patient attempts to contract muscles (e.g., quick stretch, vibration, electrical stimulation).; - Select optimal biomechanical position or position in point of range of motion for patient to initiate movement (e.g., to facilitate hip flexion, have patient assume side lying and place patient's hip in 90 degrees of flexion; also, therapist quick stretches the hip flexors as the patient attempts to contract the muscle).; - Isometric, eccentric, concentric exercises.; - Select eccentric exercises prior to concentric exercises.; - Assistive, active, and resistive exercises.; - Functional activities (e.g., bridging exercises, sit to stand, dressing, and other daily tasks, etc.).; - Train the patient in context-specific environments.
Force control--speed | - Isokinetic exercise training.; - Functional tasks requiring quick contractions (postural perturbations, kicking a ball, etc.).
Tone-- spasticity | - Stretching, prolonged stretching, passive manipulation by therapists (e.g., slow rhythmic rotation), weight bearing, ice, contraction of muscles antagonistic to spastic muscles, splinting, and casting.
Tone-- prolonged recruitment and lack of reciprocal inhibition | - Exercise muscle groups antagonistic to muscle that will not turn off with the correct timing.; - Slow active reciprocal contraction of agonist andantagonist muscles.
Synergistic organization | - Select exercises, movement patterns, and activities that require increasingly more complex combinations of muscle contractions and sequencing (e.g., ankle dorsiflexion and eversion with hip and knee extended, prehensile patterns of hand with wrist extension, elbow extension, and shoulder flexion).; - Vary conditions of performance so that patient will be able to adapt to speed and other environmental stresses.; - Functional use of available controlled movement.; - Goal is developing a variety of movement patterns and purposeful activities.
Mobility | - Practice moving in bed, rolling, coming to sit, sit to stand, transfers, standing, walking (activities may be done by encouraging as much use of involved extremities as possible, or patient may be taught to compensate with noninvolved extremities).
Balance | - Weight-shift training with and without feedback.; - Selecting activities that require automatic weight transfer (e.g., reaching).; - Practice a variety of activities under different conditions that require sitting, standing, and walking balance (reaching, turning, changing directions, carrying objects, going up and down hills, catching, throwing, and reaching in various directions).; - Patient practices restoring balance as his/her balance is perturbed.
Gait | - Consultation with orthotist to select appropriate orthosis.; - Select assistive devices.; - Practice swing, stance, weight shift components with and without feedback from therapists.; - Vary conditions of performance (speed, sensory conditions, different surfaces).
Impaired ADL | - Practice all basic activities of daily living (patient may be taught compensatory strategies with or without adaptive equipment).; - Practice all instrumental activities of daily living that the patient needs to be able to do (telephoning, using checkbook, shopping, etc.). Compensatory strategies with or without adaptive equipment.; - Practice home and community activities (independent walking in the home and community, home management tasks, etc.).

Table 15. Evidence on the effectiveness of different types of physical therapy

Author, Year, Country | Purpose, Study design Duration of deficits Number of subjects | Outcome measures Maximum followup | Conclusions/Comments
Sunderland, Tinson, Bradley, et al. (1992 and 1994) United Kingdom | Compare enhanced PT to orthodox PT RCT with stratification on side of hemiplegia and severity of upper extremity impairments Acute deficits N = 432 | Extended Motricity Index Motor Club Assessment Passive movement and pain Frenchay arm test Nine-hole peg test Sensory loss ADL (Barthel) F/U until 1 year | Improved arm function in enhanced therapy group at 6 months that was not sustained at 12 months.
Jongbloed, Stacey, and Brighton (1989) British Columbia | Compare functional and sensorimotor occupational therapies RCT Acute deficits N = 90 | ADL (Barthel) Meal preparation Sensorimotor Integration Test F/U until 8 weeks | No significant differences among groups.
Dickstein, Hocherman, Pillar, et al. (1986) Israel | Compare 3 therapeutic approaches RCT Acute deficits N = 131 | ADL (Barthel) Muscle tone Active ROM Strength Ambulatory status F/U until 6 weeks | No significant differences among groups. No difference in functional recovery or stress on caregivers.
Lord and Hall (1986) United States | Compare neuromuscular retraining (NRT) and traditional functional rehabilitation (TFR) Retrospective F/U study with matching Acute deficits N = 39 | NA F/U until 8 months | No significant differences except NRT improved more on feeding (p < 0.05).
Logigian, Samuels, Falconer, et al. (1983) United States | Compare traditional PT and neurofacilitation RCT Acute deficits N = 42 | ADL (Barthel) Manual Muscle Test F/U until discharge | No differences between groups.
Stern, McDowell, Miller, et al. (1970) United States | Compare neuromuscular reeducation and traditional PT RCT with patients added to "balance" groups Acute deficits N = 62 | Strength Mobility Index Kenny Self-Care Index F/U until discharge | No differences between groups.

Note: ADL = activities of daily living, F/U = followup, NA = not available, PT = physical therapy, RCT = randomized controlled trial, ROM = range of motion.

Rehabilitation programs do not typically employ cardiovascular training techniques, but many patients experience some degree of physical conditioning by engaging in rehabilitation activities. Patients with coexisting cardiovascular disease will require evaluation before rehabilitation and monitoring during treatment to minimize the risk of complications. The benefits of incorporating cardiovascular training programs in stroke rehabilitation need to be evaluated.

### Exercise and Functional Training for Remediation of Sensorimotor Deficits

Recommendation: Patients who have functional deficits and at least some voluntary control over movements of the involved arm or leg should be encouraged to use the limb in functional tasks and offered exercise and functional training directed at improving strength and motor control, relearning sensorimotor relationships, and improving functional performance. (Research evidence = C; expert opinion = strong consensus.)

Exercise and functional training are indicated if the motor deficit compromises the patient's ability to walk or perform ADL. Published studies report that many patients improve during rehabilitation; however, they do not convincingly establish whether improvement should be attributed to the type, intensity, frequency, and duration of treatment or to spontaneous recovery. The strongest evidence of benefit is from studies that have enrolled patients with chronic deficits or have included a no-treatment control group. For example, Wade found improvement in gait speed after outpatient rehabilitation (Wade, Collen, Robb, et al., 1992), and Smith found a graded response to increasing intensity of outpatient rehabilitation in patients with mild sensorimotor deficits (Smith, Goldenberg, Ashburn, et al., 1981). Table 10 in Chapter 5 for a summary of these studies.) Tangeman documented improved balance and ADL performance after functional training in weight-shift balance in patients who were trained a year or more after their stroke (Tangeman, Banaitis, and Williams, 1990). Using no-treatment control groups in randomized studies, Mandel found that treatment groups that received biofeedback improved more than the control group (Mandel, Nymark, Balmer, et al., 1990). (For more information, see Table 16).

Table 16. Evidence on the effectiveness of biofeedback

Author, Year, Country | Purpose, Study design Duration of deficits Number of subjects | Outcome measures Maximum followup | Conclusions/Comments
Mandel, Nymark, Balmer, et al. (1990) Canada | Compare rhythmic positional BFB to EMG BFB RCT Chronic deficits N = 37 | Active ROM of ankle Dynamic dorsi- and plantar flexion Gait analysis Energy expenditure F/U until 3 months | Walking speed of both BFB groups improved more than controls, but differences significant only for positional BFB. Energy expenditure decreased in both BFB groups.
Wolf, LeCraw, and Barton (1989) United States | Compare effects of motor copy and conventional BFB RCT N = 26 | Functional tasks Active ROM Integrated EMG levels Chronic deficits F/U until 9 months | Significant functional improvements in both groups.
Basmajian, Gowland, Finlayson, et al. (1987) Canada | Compare integrated behavioral PT with BFB to traditional PT Mix of acute and chronic deficits N = 29 | UEFT Finger oscillation Health Belief Survey Mood and affect F/U until 9 months | No significant differences between groups. Both groups improved significantly on UEFT and finger oscillation.
John (1986) United Kingdom | Examine benefits of EMG BFB in the legs RCT with crossover at 3 weeks Acute deficits N = 24 | ROM Gait speed Static contraction F/U until 6 weeks | No significant differences in function.
Mulder, Hulstijn, and van der Meer (1986) Holland | Examine benefits of EMG BFB in the legs RCT Duration of deficits not available N = 12 | ROM Gait velocity | No differences among groups.
Inglis, Donald, Monga, et al. (1984) Canada | Examine benefits of EMG BFB in the arm ROM RCT with crossover of control group Deficits < 6 months N = 30 | Strength Brunnstrom stages Post-test | No significant differences.
Basmajian, Gowland, Brandstater, et al. (1982) Canada | Compare effects of PT plus EMG BFB to PT alone RCT Deficits 2 to 5 months N = 37 | UEFT Post-test | No significant differences on any groups.
Burnside, Tobias, and Bursill (1982) United Kingdom | Compare BFB to exercise therapy for foot drop Non-RCT; matched control group Deficits > 3 months N = 22 | Strength ROM Gait (video) F/U until 6 weeks | BFB group improved significantly more on strength, ROM, and gait.
Greenberg and Fowler (1980) United States | Compare effects of kinetic BFB on elbow extension to OT alone RCT Chronic deficits N = 20 | Active elbow extension Post-test | No differences among groups.
Hurd, Pegram, and Nepomuceno (1980) United States | Compare EMG BFB to PT only and PT plus simulated BFB RCT Patients and muscles within patients randomly assigned Mean > 60 days N = 44 | Muscle activity Active ROM Post-test | Both BFB groups improved more than control "PT only" groups. No differences between BFB and simulated BFB groups.
Shiavi, Champion, Freeman, et al. (1979) United States | Compare effects of EMG BFB in the leg to sham BFB and PT alone RCT Acute deficits N = 22 | Muscle control Manual muscle test | Results difficult to interpret.
Basmajian, Kukulka, Narayan, et al. (1975) United States | Compare effects on foot drop of BFB to PT alone RCT Deficits > 3 months N = 20 | Strength Active ROM Gait analysis F/U up to 16 weeks | Trends favor BFB but differences not significant

Note: BFB = biofeedback, EMG = electromyographic, F/U = followup, OT = occupational therapy, PT = physical therapy, RCT = randomized controlled trial, ROM = range of motion, UEFT = Upper Extremity Function Test.

Patients with mild sensorimotor deficits following stroke may not require any therapeutic intervention. However, evidence from the geriatric literature suggests that accumulated mild deficits in strength, mobility, and coordination contribute to limited physical performance in the elderly (Duncan, Chandler, Studenski, et al., 1993) and increase the risk of falls (Bergstrom, Aniansson, Bjelle, et al., 1985; Jette and Branch, 1981; Lord, Clark, and Webster, 1991; Lundgren-Linquist, Aniansson, and Rundgren, 1983; Studenski, 1992; Studenski, Duncan, and Chandler, 1991; Whipple, Wolfson, and Amerman, 1987). Increasing strength and balance may improve function and reduce falls in these patients (Fiatarone, Marks, Ryan, et al., 1990; Judge, Lindsey, Underwood, et al., 1993; Tinetti, Baker, McAvay, et al., 1994; Tinetti and Ginter, 1988).

Another important issue is that of sustaining levels of function achieved during rehabilitation. Most studies report only short-term outcomes. Those that examine longer-term outcomes reach mixed conclusions. Some of these studies indicate that functional gains are maintained (Indredavik, Bakke, Solberg, et al., 1991; Smith, Goldenberg, Ashburn, et al., 1981; Strand, Asplund, Eriksson, et al., 1985), and others do not (Garraway, Akhtar, Hockey, et al., 1980; Garraway, Akhtar, Prescott, et al., 1980; Garraway, Walton, Akhtar, et al., 1981; Sivenius, Pyorala, Heinonen, et al., 1985; Stevens, Ambler, and Warren, 1984; ; Wade, Collen, Robb, et al., 1992). Failures to maintain functional gains appear to underscore the need for continued practice after the patient returns home. The importance of encouragement by family and involved others and the need for the patient to accept progressively more responsibility for independent function can hardly be overemphasized. Continued rehabilitation or "tuneups" may be indicated in some cases, but need to be justified by evidence of progress during treatment and deterioration in its absence.

### Evidence on Specific Interventions for Sensorimotor Deficits

Neither research evidence nor expert consensus adequately supports recommendations concerning the superiority of one type of exercise regimen over another, the use of biofeedback or functional electrical stimulation in enhancing responses to functional therapy, the functional benefits of balance retraining, or the use of sensory retraining. The results of controlled studies are summarized in the indicated tables. Conclusions are:

- Biofeedback
- . Results of biofeedback studies (see Table 16) are inconclusive. Two studies have demonstrated sustained functional benefits (Burnside, Tobias, and Bursill, 1982; Mandel, Nymark, Balmer et al., 1990). Other studies have shown transient or no effects. Two meta-analyses have also come to conflicting conclusions. (Schleenbaker and Mainous) (1993) found that biofeedback is an "effective tool for neuromuscular reeducation" while (Glanz, Klawansky, Stason, et al. (1994a)) found an insignificant positive effect in pooled studies. Differences in the criteria for selecting studies to be pooled, and differences in the outcome measures used, account for the differing results in these two meta-analyses.
- Functional electrical stimulation
- . Functional electrical stimulation (FES) has been shown to produce short-term increases in muscle strength and motor control in selected patients (see Table 17); however, effects on function have not been adequately studied (Glanz, Klawansky, Stason, et al., 1994b).
- Balance training.
- Computerized biofeedback training designed to improve balance (see Table 18)has been shown to have greater effects on impairment measures (lateral sway, stance symmetry, etc.) than physical therapy alone, but carry over to improved locomotor performance has not been demonstrated.
- Different types of exercise
- . No clear advantage has been demonstrated of adding isokinetic, resisted, or active exercise regimens to functional therapy alone (see Table 19).
- Sensory retraining
- . Chronic sensory deficits are often refractory and one recent study (see Table 19) found that sensory retraining improved performance on tests of impairment; however, the study did not examine measures of function (Yekutiel and Guttman, 1993).

Table 17. Evidence on the effectiveness of functional electrical stimulation with or without biofeedback

Author, Year, Country | Purpose, Study design Duration of deficits Number of subjects | Outcome measures Maximum followup | Conclusions/Comments
Kraft, Fitts, and Hammond (1992) United States | Compare two types of FES, proprioceptive PT, and no treatment in the arm Non-RCT with matched control groups Chronic deficits N = 18 | Fugl-Meyer Grip strength F/U up to 9 months | Results favor EMG stimulation group.
Levin and Hui-Chan (1992) Canada | Test effectiveness of transcutaneous electrical nerve stimulation (TENS) in chronic spasticity of lower extremities RCT with placebo control Chronic deficits N = 13 | Spasticity score Reflex profile Maximal contraction F/U at 3 weeks | Significant differences in outcomes favored TENS.
Cozean, Pease, and Hubbell (1988) United States | Compare the effects on gait of FES, BFB, and the combination RCT Mixed acute and chronic deficits N = 36 | Quantitative gait analysis (videos) F/U at 6 weeks | Results favor combined BFB and FES.
Winchester, Montgomery, Bowman, et al. (1983) United States | Compare effects of positional feedback plus FES to PT alone on knee extension RCT Deficit < 6 months N = 40 | Passive and active ROM Maximum isometric knee extension torque F/U at 4 weeks | Differences on knee extension torque favor BFB plus FES group.
Bowman, Baker, and Waters (1979) United States | Compare effects on wrist extension of positional BFB and FES to PT alone RCT 3 weeks to 4 months N = 30 | Wrist extension torque Active ROM F/U at 4 weeks | Differences on both outcomes favor BFB plus FES group.
Merletti, Zelaschi, Latella, et al. (1978) Italy | Compare effects on ankle dorsiflexion of FES to PT alone RCT Deficits 1 to 15 months N = 49 | Maximum voluntary movement F/U at 4 weeks | Improvement greater in FES group (p = 0.007).
Takebe, Kukulka, Narayan, et al. (1976) United States | Compare effects of FES, PT plus BFB, and PT alone in spastic lower extremity Deficits > 3 months N = 15 | Gait analysis Ankle dorsiflexion ROM Post-test | Qualitative analysis favors BFB and FES groups.

Note: BFB = biofeedback, EMG = electromyographic, FES = functional electrical stimulation, F/U = followup, PT = physical therapy, RCT = randomized controlled trial, ROM = range of motion, TENS = transcutaneous electrical nerve stimulation.

Table 18. Evidence on the effectiveness of treatment of disturbed balance

Author, Year, Country | Purpose, Study design Duration of deficits Number of subjects | Outcome measures Maximum followup | Conclusions/Comments
Tangeman, Banaitis, and Williams (1990) United States | Test whether rehab improves balance and function Time series Chronic deficits N = 40 | Weight-shift balance ADL F/U until 3 months | Significant improvement on all measures that was sustained at 3 months.
Winstein, Gardner, McNeal, et al. (1989) United States | Compare effect of PT plus retraining to PT alone Non-RCT with matched control group Acute deficits N = 42 | Static center of pressure position Weight distribution Locomotor performance, gait pattern, coordination F/U at 3 to 4 weeks | Better standing symmetry in experimental group, but no differences in stability during locomotor performance.
Shumway-Cook, Anson, and Haller (1988) United States | Compare PT plus balance retraining and static force platform BFB to PT alone RCT Deficits < 6 months N = 16 | Lateral sway displacement Sway area F/U at 2 weeks | Lateral sway displacement reduced in experimental group, but no differences in total sway area.
Hocherman, Dickstein, and Pillar (1984) Israel | Compare PT plus platform training to PT alone Non-RCT with matched control group Acute deficits N = 24 | Maximal Movement Amplitude (MMA) Weight distribution F/U at 3 weeks | Experimental group improved stance stability and weight distribution more.

Note: ADL = activities of daily living, BFB = biofeedback, F/U = followup, PT = physical therapy, RCT = randomized controlled trial, Rehab = rehabilitation

Table 19. Evidence on the effectiveness of other interventions to treat sensorimotor deficits

Author, Year, Country | Purpose, Study design Duration of deficits Number of subjects | Outcome measures Maximum followup | Conclusions/Comments
Taub, Miller, Novack, et al. (1993) United States | Examine the effects of restraining the unaffected arm RCT Chronic deficits N = 9 | Emory Motor Function Test Arm Motor Activity Test (AMAT) Motor Activity Log Videotaped Motor Test F/U until 2 years | Restraint group improved more on multiple measures. Effects maintained at 2 years.
Yekutiel and Guttman (1993) Israel | Evaluate effects of sensory retraining Non-RCT with matched controls Chronic deficits N = 39 | Location of touch Elbow position 2-point discrimination Stereognosis F/U at 6 weeks | Significant differences favored sensory retraining group on all measures.
Wolf, LeCraw, Barton, et al. (1989) United States | Examine effects of "forced use" on the paretic arm Time series Chronic deficits N = 21 | 21 timed activities 3 force measures F/U until 12 months | Forced use led to significant improvement in timed tasks. Effect maintained at 1 year.
Glasser (1986) United States | Compare effects on ambulation of PT plus isokinetic exercise to PT alone RCT Deficits 3 to 6 months N = 20 | Functional Ambulation Profile Ambulation time F/U at 5 weeks | No differences among groups.
Trombly, Thayer-Nason, Bliss, et al. (1986) United States | Compare different types of exercises on finger extension RCT Acute deficits N = 20 | ROM Tapping Grasp/release Daily pre- and post-tests | No significant differences among groups.
Inaba, Edberg, Montgomery, et al. (1973) United States | Compare functional training, active exercise, and restrictive exercise RCT Deficits < 4 months N = 77 | ADL Extension strength F/U until 2 months | No significant differences among groups at 2 months.

Note: ADL = activities of daily living, F/U = followup, PT = physical therapy, RCT = randomized controlled trial, ROM = range of motion

### Compensatory Techniques To Improve Functional Performance

Recommendation: Patients with persistent, nonremediable, functional deficits should be taught compensatory methods for performing important tasks and activities, using the affected limb when possible and, when not, the unaffected limb. (Research evidence = NA; expert opinion = strong consensus.)

Compensatory treatments address the tasks and activities that comprise meaningful roles for a person. Examples are:

- Self-care tasks or basic ADL
- . The ability to take care of basic personal needs including feeding, bathing, toileting, dressing, and grooming.
- Complex tasks, or IADL
- . The ability to perform more complex daily activities such as using the telephone, writing, cutting fingernails, driving a car, managing the home, and managing finances.
- Social, recreational, and spiritual roles
- . Examples are maintaining friendships, being an active parishioner, and pursuing valued hobbies.
- Work
- . The ability to engage in activities for financial remuneration.

Deficits that interfere with independence in these roles include:

- Inability to use an arm or hand to stabilize an object or perform an activity that requires the use of both arms or hands.
- Disturbed sensation or astereognosis (inability to perceive an object by feel alone), which prevents doing activities with tools or utensils out of the line of vision.
- Disturbed body scheme or spatial relationships which interfere with manipulating objects in the environment or in relation to one's own body. Unilateral neglect is particularly limiting because the person fails to pay attention to anything in the neglected space and will, for example, eat only food on one side of the plate, shave only one side of the face, fail to dress one side of the body, and bump into objects on one side.
- Topographic agnosia, a perceptual impairment that limits independent mobility by preventing the person from finding the way from one place to another.
- Limited mobility, which interferes with turning over in bed, making transfers between bed and chair or toilet, or negotiating stairs.
- Communication problems that interfere with family relationships or are deterrents to the resumption of social and vocational roles.
- Alexia (inability to read) and agraphia (inability to write), which interfere with home management, financial management, some social roles, and work.
- Apraxia (inability to do purposeful movement that is not attributed to sensory or motor deficits), which can interfere with all tasks and activities, although the ability to do habitual tasks may be preserved enough in some patients to allow semi-independence in self care.
- Cognitive deficits that prevent the patient from understanding even one-step commands and preclude independence in most role functions.
- Incoordination or lack of dexterity in the nondominant hand when the dominant hand was the one affected by the stroke. This can severely limit independence. Practice and perseverance are needed to learn to use the nonaffected arm.
- Perceptual deficits and problems with motor learning, which have deleterious effects on the ability to perform tasks of daily living.

The objective of compensatory treatment is to help patients learn new skills that permit them to perform desired activities despite persisting motor, sensory, or cognitive deficits. Training begins with relatively simple tasks and progresses gradually to more difficult ones until the patient's limits are reached. Graduated challenges offer the opportunity for success and with it an increasing sense of competency, mastery, and self-esteem. Many adaptive methods aim to teach patients to perform tasks with one hand. Examples include ways to stabilize objects or clothing while working on them with the unimpaired arm or ways to fasten clothing with one hand.

Achievements are highly individual. Even patients who only have the ability to follow one-step commands and must use a wheelchair can achieve some independence in simple self-care tasks in a supportive environment. Without support, such patients are likely to require custodial care.

Most evidence supporting the effectiveness of compensatory techniques is indirect and depends on studies that show improvement in patient function during rehabilitation, but either do not test a particular technique or do not control for the effects of spontaneous neurological recovery. Exceptions are controlled studies that have found short-term increases in walking speed in response to training regimens (Cozean, Pease, and Hubbell, 1988; Mandel, Nymark, Balmer, et al., 1990; Wade, Collen, Robb, et al., 1992).

### Adaptive Devices, Durable Equipment, and Orthotic Devices

Recommendation: Adaptive devices should be used only if other methods of performing the task are not available or cannot be learned. The device should have proven reliability and safety, and the patient and/or caregiver should be thoroughly trained in its proper use. (Research evidence = NA; expert opinion = consensus.)

Many different types of adaptive devices and durable medical equipment are available to assist the patient in becoming more independent (examples are provided in Table 20). Need is determined by the type and level of the patient's functional deficit(s), the degree of adaptation achieved, and the structural characteristics of the living environment.

Table 20. Examples of adaptive devices and durable equipment

- Eating devices; - Built-up handles on utensils for weak or incomplete grasp.; - Rocker knife for one-handed cutting.; - Nonskid mats to stabilize plate for eating with one hand.; - Plate guards or scoop dishes for scooping food off the plate when eating one-handed.; - Cups that hold liquid in the upper part and reduce the need to tilt the head when drinking, for patients with a swallowing problem who are at risk of aspiration.; - Bathing and grooming devices; - Long-handled sponge for limited reach.; - Washcloth or sponge mitt for patients with a weak grasp.; - Electric razors with specially adapted heads (e.g., at 90 degrees to the handle).; - Hand-held shower nozzle.; - Nonskid mats secured in tub or shower to prevent slipping and falling.; - A wide selection of grab bars for use in tub or shower that require assessment of the patient's level of need, and the architectural limitations of the bathroom before selecting the design.; - Toileting aids; - Bedside commode, urinal, bedpan.; - Elevated toilet seat.; - Toilet seat with rails.; - Grab bars next to the toilet.; - Shower and tub aids; - Shower and tub seats designed for decreased ability to stand in shower or sit down in or rise from the tub.; - Shower and tub transfer seats for difficulty with shower and tub transfers and difficulty with standing in shower or sitting in tub.; - Shower chairs that can be pushed into wheelchair-accessible shower for inability to transfer or stand while showering.; - Hydraulic and motorized tub lifts if the patient is unable to get into or out of tub; use depends on architecture of bathroom.; - Dressing equipment; - Velcro closures for one-handed dressing.; - Elasticized shoestrings for one-handed dressing.; - Long-handled shoe horn when reach is limited.; - Walking devices; - Cane with a single point of contact that improves stability of gait when leg is weak. Cane should be fitted to the patient and have a rubber tip to improve traction.; - Tripod or quad cane with three or four points of contact. These provide greater stability but are bulkier and more difficult to handle.; - Folding cane chair, allowing the user to walk and then sit and rest.; - Walkers that differ according to structure and purpose but must be lightweight and fold if the patient is to use them outside the home.; - Adjustable pickup walkers for patients who need support to stand and walk, and are able to lift the walker and maintain balance.; - Reciprocal walkers for patients who might lose their balance when lifting a regular walker.; - Rolling walkers that increase energy-efficient walking, but may be too unstable for some patients.; - Wheelchair and wheelchair cushions; - Wheelchair. Wheelchair selection is based on body measurements, specific needs (e.g., elevating leg rests), safety, comfort, and maneuverability. A wheelchair for patients with hemiplegia may have a lowered base of support and lowered seat to permit the patient to use the uninvolved foot to propel the wheelchair or a one-armed drive that allows maneuvering with one arm and hand.; - Wheelchair cushion. This is important for comfort and to prevent skin breakdown; selection is based on the patient's mobility status, body build, nutrition, and skin condition.; - Transfer devices; - Plastic or wooden transfer board to assist the patient who is unable to stand to perform bed, chair, shower, tub, or car sliding transfers.; - Gait/transfer belt for use by caregiver, if indicated.; - Hydraulic lifts for bed, chair, tub, or car transfers.; - Hydraulic or electric stair lifts for patients unable to climb stairs.; - Chairs modified to have higher seats for patients unable to lift out of seat. Electrically or mechanically powered chairs with seats that raise are available but are rarely indicated.; - Leisure and recreation devices; - Automatic card shufflers.; - Card holders.; - Large-faced cards.; - Books on audio tape.; - Swimming flotations.; - Fishing pole harnesses.; - Gardening tools with builtup handles.; - Specially designed golf clubs.

Use of a device should not substitute for reasonable efforts to teach a patient a method for performing the task in question. In most instances, mastery of the method will allow greater flexibility, satisfaction, and independence. The device may serve as a useful supplement, however, or permit a function to be performed if the adapted method cannot be learned or requires too much effort.

The patient and family/caregivers should be involved in the selection of adaptive devices and should be thoroughly trained in their use. Adequate attention to these matters will increase the likelihood that the device is wanted, is sufficient to meet needs, and will be fully used. Since some of these devices are expensive, the patient's financial circumstances and insurance coverage also need to be explored.

Recommendation: A wheelchair prescription for a patient with severe motor weakness or easy fatigability should be based on careful assessment of the patient and the environment in which the wheelchair will be used. Wheelchair selection should have the full support of the patient and family/involved others. (Research evidence = NA; expert opinion = strong consensus.)

Wheelchair designs vary widely and need to be adapted to the patient's special needs. Comfort, safety, proper posture, and access to home and community resources are important considerations. These objectives can be achieved only through careful assessment of both the patient and the environment, and through responsiveness to the wishes of patient and family.

Recommendation: Lower extremity orthotic devices should be considered if ankle or knee stabilization is needed to help the patient walk. Prefabricated bracing can be used initially, and more expensive customized bracing reserved for patients who demonstrate a long-term need. (Research evidence = NA; expert opinion = consensus.)

Timely use of orthotic devices can facilitate ambulation, permit gait training to be conducted simultaneously with muscle control exercises, and reduce the energy cost of ambulation in the presence of hemiparesis (Corcoran, Jebsen, Brengelmann, et al., 1970). Use of orthotic devices should not, however, be substituted for functional exercise directed at improving muscle strength and control, if the prognosis for recovery of motor control is good.

## Preventing and Treating Complications

Prevention of complications such as aspiration pneumonia, dehydration or malnutrition, skin breakdown, urinary tract infections, and falls was discussed in Chapter 4. This section addresses the prevention of falls in a rehabilitation setting and the prevention and treatment of muscle spasticity and contracture, shoulder injuries, and pain syndromes.

### Fall Prevention

Recommendation: The patient's risk of falling should be evaluated on admission to a rehabilitation program, and preventive measures should be taken that are appropriate to the patient's deficits. (Research evidence = NA; expert opinion = strong consensus.)

Patients with strokes have 61 to 83 percent of all falls that occur in rehabilitation hospitals (DeVincenzo and Watkins, 1987; Mion, Gregor, Chwirchak, et al., 1989). Many of the same considerations concerning fall prevention apply as discussed previously in Chapter 4. The major difference is that the patient's risk of falling is increased by rehabilitation treatments aimed at increasing mobility. Safety measures need to anticipate these risks and ensure environmental precautions and adequate supervision.

Muscle weakness, problems with gait or balance, difficulties with transfers, altered sensation, postural hypotension, impaired vision, and confusion or disorientation each increase the risk of falls. Falls are particularly likely when the patient tries to reach the toilet without assistance. Acute illnesses, generalized weakness, and drug side effects compound risks due to neurological deficits. Patients with visual neglect who are slow in performing tasks are at high risk of multiple accidents (Diller and Weinberg, 1970); and wheelchair users with visuospatial deficits are at increased risk of running into obstacles (Webster, Rapport, Godlewski, et al., 1994). Behavioral impulsivity, older age, a history of previous falls, and multiple transfers are associated with an increased risk of falling (Rapport, Webster, Fleming, et al., 1993). Equally important as injuries from falls is the possibility that fear of falling may compromise a patient's confidence and reduce motivation to walk or attempt self-care activities.

Facilitywide fall prevention programs need to address environmental hazards such as accessibility of toileting facilities, inadequate lighting, and wet and slippery floors. Patient risk profiles for falling should be updated at regular intervals to reflect changes in functional status and activity level. Timely assistance to satisfy bathroom needs, adequate supervision during rehabilitation sessions and intervening periods of practice, and patient and family education in fall prevention strategies are all important. Medication regimens should be adjusted to avoid sedation, confusion, or postural hypotension. Technologic approaches such as antitipping devices on wheelchairs, bed and chair alarm systems, wedge seat cushions, and--as a last resort--use of restraints are helpful in some patients.

Despite preventive measures, falls do sometimes occur. It is important that patients be taught how to get up after a fall and that family members be taught how to evaluate the possibility of a fracture, and if a fracture has not occurred, to help the patient get up. Most falls can be managed without outside assistance.

### Spasticity and Contractures

Recommendation: Spasticity and contractures should be treated/ prevented by antispastic pattern positioning, range-of-motion exercises, stretching and/or splinting. (Research evidence = NA; expert opinion = consensus.)

Contractures that restrict movement of the involved joint or are painful will impede rehabilitation and may limit the patient's potential for recovery. Paretic limbs with muscle spasticity are at especially high risk of developing contracture. Prevention is the key to effective management. Traditional measures are to support the limb in an anatomically correct position that opposes the usual pattern of spasticity, and to move it through its full ranges of motion at regular intervals. The limited evidence from controlled trials of treatments for spasticity in patients with strokes is summarized in Table 21. Manual stretch may be effective with selected patients (Carey, 1990). The use of medications to treat spasticity is controversial. For example, one randomized trial found that dantrolene sodium had no effect on the spastic limb but decreased strength in the unaffected limb (Katrak, Cole, Poulos, et al., 1992).

Table 21. Evidence on the effectiveness of treatment for spasticity

Author, Year, Country | Purpose, Study design Duration of deficits Number of subjects | Outcome measures Maximum followup | Conclusions/Comments
Katrak, Cole, Poulos, et al. (1992) Australia | Examine effects of dantrolene sodium on spasticity and muscle strength Double-blinded RCT with crossover Acute deficits N = 31 | Motor Assessment Scale (MAS) Cybex isokinetic dynamometer ADL (Barthel) F/U until 13 weeks | Dantrolene sodium decreased strength in unaffected limbs but had no effect in impaired limbs.
Carey (1990) United States | Examine effects of manual stretch on finger control RCT Chronic deficits N = 24 | EMG ratios of flexor and extensor muscles Joint Movement Tracking Test (JMTT) Force Tracking Test (FTT) Immediate post-test | Stretch group improved more than stroke controls on JMTT but not on FTT.
Poole, Whitney, Hangeland, et al. (1990) United States | Test effects of inflatable pressure splints on upper extremity function RCT with matched pairs design Duration of deficits not available N = 18 | Fugl-Meyer F/U at 3 weeks | No significant differences.

Note: ADL = activities of daily living, EMG = electromyographic, F/U = followup, RCT = randomized controlled trial.

If a contracture interferes with function, corrective measures include splinting or casting involved joints into progressively more anatomically correct positions and surgical corrections. One study that used inflatable splints in the arm was inconclusive (Poole, Whitney, Hangeland, et al., 1990). Motor-point nerve blocks using phenol or botulinum toxin may have roles in selected patients (Awad and Dykstra, 1990), but their effectiveness in stroke has not been studied in controlled trials.

### Shoulder Injury and Pain Syndromes

The patient with a stroke may experience pain from arthritis, peripheral vascular disease, or osteoporosis; may develop pain from muscle spasms or soft tissue or joint injury in a paretic limb; or may experience specific types of pain syndromes such as reflex sympathetic dystrophy or the thalamic pain syndrome.

Recommendation: The prevention of shoulder injuries should emphasize proper positioning and support and avoidance of overly vigorous range-of-motion exercises. (Research evidence = C; expert opinion = strong consensus.)

Some degree of shoulder pain has been reported in as many as 70 to 84 percent of patients with a paralyzed upper extremity (Brandstater and Basmajian, 1987; Roy, 1988) but is severe in only a small percentage of patients. The shoulder is especially vulnerable to injury because the joint capsule depends on the surrounding muscle cuff for support. Flaccid paralysis permits gravitational pull to stretch the joint capsule. Prolonged pain, "frozen" shoulder, and decreased functional independence are potential results of shoulder injury.

Prevention, first and foremost, requires awareness of susceptibility to shoulder injury. Preventive measures include supporting the shoulder in a position that maintains a normal scapulo-humoral orientation, using lap trays on wheelchairs, using a pull sheet rather than lifting under the arms to pull the patient up in bed, and maintaining proper positioning and support in bed and while sitting or standing. Range-of-motion exercises should not carry the shoulder beyond 90 degrees of flexion and abduction unless there is upward rotation of the scapula and external rotation of the humeral head. Patients who are taught self-range of motion should be cautioned to avoid excessive shoulder flexion. Use of an overhead pulley appears to increase the frequency of pain (Kumar, Metter, Mehta, et al., 1990). The use of slings or arm supports is controversial because of the potential complications from immobilization.

Reflex sympathetic dystrophy (RSD), which has been reported in 12 to 25 percent of patients with hemiplegia (Brandstater and Basmajian, 1987), is characterized by pain, swelling, stiffness, and discoloration of the involved limb and shoulder. Its cause is not fully understood, but immobility, venous pooling, altered muscle tone, and inflammation of the shoulder joint appear to contribute. Treatment of RSD involves graded and carefully selected range-of-motion exercises, heat, compression, high-dose anti-inflammatory agents, pulse steroid therapy, pain medications, sympathetic nerve blocks, and therapeutic positioning (Borgman and Passarella,1991; Brandstater and Basmajian, 1987; Johnston and Olson, 1980).

## Managing Cognitive and Perceptual Deficits

Recommendation: Cognitive deficits that preclude effective learning are contraindications to rehabilitation. Cognitive and perceptual problems not severe enough to preclude rehabilitation require goal-directed treatment plans. (Research evidence = NA; expert opinion = strong consensus.)

Knowledge of the patient's cognitive and perceptual limitations is important in planning and conducting the rehabilitation regimen, helping to prepare the patient for functioning safely after the return home, and predicting the ability to resume vocational activities.

Cognitive deficits may involve problems with attention, orientation, concentration, learning (short-term memory), or problem solving. Common specific patterns are unilateral neglect (or hemi-inattention) and apraxia. Unilateral neglect is a disturbance of a patient's awareness of space on the side of the body opposite the location of the stroke-causing lesion. Apraxia is a disorder of learned movement that cannot be explained by the patient's deficits in strength, coordination, sensation, or comprehension.

Diffuse cognitive deficits occur more frequently in patients with large frontal strokes, visuospatial deficits in right hemisphere strokes, and apraxia in left hemisphere strokes. The true frequency of these deficits is obscured by their diverse manifestations and by the use of varying diagnostic criteria (Schenkenberg, Bradford, and Ajax, 1980; Wilson, Cockburn, and Halligan, 1987). In the Framingham Study cohort, cognitive performance was found to be significantly lower 6 months after a stroke than before the event (Kase, Wolf, Kelly-Hayes, et al., 1987). Cognitive disturbances tend to improve after a stroke but may persist for months or years. One population-based study found that 29 percent of patients still had problems with memory 3 months after returning to the community (Wade, Parker, and Langton-Hewer, 1986). Unilateral neglect has been reported in as many as half of patients with right brain damage and in 20 to 25 percent of patients with left brain damage 3 months after the onset of stroke (Fullerton, McSherry, and Stout, 1986; Stone, Wilson, Wroot, et al., 1991), but estimates of incidence vary due to differences in the populations studied, time since onset of stroke, and the assessment measures used.

Perceptual problems impede performance of many activities of daily living (Ben-Yishay, Gerstman, Diller, et al., 1970; Denes, Semenza, Stoppa, et al., 1982; Kinsella and Ford, 1980; Wade, Wood, and Hewer, 1988). Patients with spatial constructional problems have difficulty dressing, eating, walking, and grooming (Warren, 1990), and those with unilateral neglect experience difficulty in academic tasks (reading, writing, arithmetic), grooming, reading a menu, using a telephone, and driving an automobile (Gordon and Diller, 1983; Titus, Gall, Yerxa, et al., 1991). Effects on task performance depend on the pattern of cognitive deficits. For example, patients with left hemiparesis often experience accidents that are related to difficulties in dealing with space, while accidents in patients with right hemiparesis are often related to slowness in processing information (Diller and Weinberg, 1970).

Unawareness of the stroke (or its manifestations) is often found in patients with lesions in the nondominant hemisphere. It can lead to impulsive, unsafe behavior in a patient who may otherwise appear relatively normal with respect to physical functioning. In general, the degree of unawareness is related to the extent of brain damage (Levine, 1990) and the degree of cognitive impairment (Diller and Weinberg, 1993). Flagrant denial is usually found in patients with severe mental confusion who are unlikely to be admitted to rehabilitation programs. Denial of specific impairments or areas of disability is common, however, and poses special challenges. In general, patients are more aware of motor impairments than of cognitive impairments or emotional problems (Anderson and Tranel, 1989; Hibbard, Gordon, Stein, et al., 1992). There are no standard approaches to managing unawareness. The therapist needs to characterize its dimensions and develop strategies to minimize its effects (Levine, 1990).

The presence of cognitive or perceptual deficits often increases the severity of functional disabilities, causes emotional distress, interferes with the patient's ability to participate in and learn during rehabilitation, and increases the risk of injury. Cognitive and perceptual deficits may also interfere with personal, family, and environmental adaptation after the return home, and require special efforts to prepare the patient and family for transition.

Treatments for cognitive and perceptual deficits emphasize retraining, substitution of intact abilities, and compensatory approaches. Goals are to remediate the impairment or to reduce the impact of the deficit through repetitive exercises or compensatory treatments that teach patients new methods of response. Evidence of the effectiveness of these techniques (see Table 22)is limited to short-term effects on outcome measures that share stimulus characteristics with the intervention (Carter, Caruso, Languirand, et al., 1980; Gordon, Hibbard, Egelko, et al., 1985; Soderback, 1988). Several studies have demonstrated the ability to train patients to improve their visual scanning skills, somatosensory awareness, and visual perception skills; however, no study has demonstrated that these skills persist or carry over to functional activities (Gordon, Hibbard, Egelko, et al., 1985; ; Weinberg, Piasetsky, Diller, et al., 1982). Case studies that have combined skill training with training in a functional activity are inconclusive. Strategies that have been tried for treating neglect include caloric stimulation (Rubens, 1985), Fresnel prisms (Rossi, Kheyfets, and Reding, 1990), eye-patching (Butter and Kirsh, 1992), dynamic stimulation (Butter, Kirsch, and Reeves, 1990), and optokinetic stimulation (Pizzamiglio, Frasca, Guariglia, et al., 1990); however, there is no evidence of lasting benefits from these.

Table 22. Evidence on the effectiveness of treatment for cognitive and perceptual deficits

Author, Year, Country | Purpose, Study design Duration of deficits Number of subjects | Outcome measures Maximum followup | Conclusions/Comments
Robertson, Gray, Pentland, et al. (1990) United Kingdom | Test effectiveness of microcomputer programs for unilateral visual field neglect "Semi-RCT" with randomized blocks of severely and mildly affected patients Group means of 11 and 19 weeks N = 36 | Behavior Inattention Test (BIT) Psychometric battery F/U until 6 months | No significant differences among groups.
Rossi, Kheyfets, and Reding (1990) United States | Test effects of Fresnel prisms in homonymous hemianopsia or visual neglect RCT Acute deficits N = 39 | Battery of visual perception tests ADL (Barthel) Number of falls F/U until 4 weeks | Prisms improved scores on visual perception tests (p < 0.01), but differences not significant for ADL or falls.
Soderback (1988) Sweden | Test effects of intellectual function and intellectual housework training Housework RCT Group means of 60 and 81 days N = 70 | Intellectual Function Assessment (IFA) Intellectual Assessment (IHA) Psychometric battery F/U until 6 months | Initial benefits of training on IHA measures not sustained at 6 months.
Gordon, Hibbard, Egelko, et al. (1985) United States | Test effects of specific training protocols in visual perceptive disorders "Quasi-RCT" (alternate wards) Acute deficits > 4 weeks N = 77 | Extensive test battery F/U until 4 months | Experimental group improved more on specifically trained skills, but differences not sustained.
Carter, Howard, and O'Neil (1983) United States | Test effects of cognitive skill remediation RCT Acute deficits N = 33 | Visual scanning Visuospatial matching to sample Time estimation Post-test | Significant differences on all measures.
Carter,Caruso, Languirand, et al. (1980) United States | Test effects of cognitive skill remediation RCT Acute deficits N = 37 | Letter cancellation Visuospatial matching Digit span Verbal-free recall Time estimation Post-test | Experimental group improved more on letter cancellation and visuospatial matching. Results based on only 18 of 27 randomized patients.
Weinberg, Diller, Gordon, et al. (1979) United States | Test effects of visual scanning, spatial organization, and sensory awareness training in patients with right brain damage RCT Deficits > 4 weeks N = 53 | Psychological test battery (26 scores on 17 tests) F/U at 4 weeks | Experimental group improved significantly more on multiple tests. Effects greater in more severely impaired patients.
Weinberg, Diller, Gordon, et al. (1977) United States | Test effects of visual scanning training in patients with right brain damage RCT Deficits > 4 weeks N = 57 | Test battery (14 tests) F/U at 4 weeks | Significant differences on multiple tests.
Taylor, Schaeffer, Blumenthal, et al. (1971) United States | Test effects of perceptual training in patients with right brain damage RCT Deficits < 6 months N = 78 | Percept-Concept-Motor Function (PCMF) ADL Brunnstrom stages Social service interview Post-test | No differences among groups.

Note: ADL = activities of daily living, F/U = followup, RCT = randomized controlled trial.

The goal of treatment for apraxia is to restore the person's ability to perform appropriate habitual or novel movements. Treatments include manually guided movement, graded use of objects and contexts that evoke automatic motor responses, mental imagery, and backward chaining. However, evidence supporting the effectiveness of these treatments is limited.

## Managing Emotional Disorders

### Diagnosing and Treating Depression

Recommendation: A high index of suspicion needs to be maintained and appropriate steps should be taken to determine the presence and cause of depression. The diagnosis of depression depends primarily on the clinical examination, supplemented when necessary by the use of selected depression scales. (Research evidence = A; expert opinion = strong consensus.)

Depression is common after stroke, either as a direct biologic effect of the brain damage or as a reaction to disabling illness, and has been reported in 11 to 68 percent of patients, including major depression in 10 to 27 percent of patients (Eastwood, Rifat, Nobbs, et al., 1989; Ebrahim, Barer, and Nouri, 1987; Gordon, 1992; House, Dennis, Morgridge, et al., 1991; Morris, Robinson, and Raphael, 1990; Robinson and Benson, 1981; Robinson, Starr, Kubos, et al., 1983; Robinson and Szetela, 1981; Wade, Legh-Smith, and Hewer, 1987). Estimates vary with the diagnostic criteria used (Gordon, 1992). The time since stroke onset is also a factor, since depression tends to develop over time and is more likely to be diagnosed as rehabilitation proceeds than during the acute hospitalization or at the time of the baseline evaluation.

Depression in stroke can have many etiologies. These include (1) a normal reaction to the losses caused by a stroke, (2) an exacerbation of preexisting depressive personality features, (3) a specific psychiatric disorder such as major depression, (4) a medical condition (e.g., hypothyroidism or Addison's disease), (5) a medication (sedatives, antihypertensives), or (6) organic brain damage. Depression can produce cognitive deficits including problems with orientation, language, visual construction, motor function, and frontal lobe tasks (Bolla-Wilson, Robinson, Starkstein, et al., 1989), especially after left hemisphere injury (Downhill and Robinson, 1994; House, Dennis, Warlow, et al., 1990). Major depression has been linked to infarcts in the left anterior cerebral cortex and basal ganglia, minor depression to right-side posterior lesions and apathy, and paradoxical cheerfulness to right anterior lesions (Robinson and Benson, 1981; Robinson and Szetela, 1981). Often, depression in stroke is associated with more than one etiology. Only a weak relationship has been shown between the severity of depression and the severity of motor or cognitive impairment after stroke (Depression Guideline Panel, 1993 [sponsored by AHCPR]).

A diagnosis of depression should be considered when the patient persistently appears depressed; gives evidence of diminished interest in activities, loss of energy, loss of appetite, sleep disturbances, or an agitated state; or expresses feelings of worthlessness, impaired concentration, or suicidal thoughts. Changes from pre-stroke behaviors observed by family members and a history of previous depression may provide valuable clues.

A clinical interview by a knowledgeable mental health professional is the most effective method of diagnosis (assessment is discussed in Chapter 3).

Recommendation: The choice of treatment for depression will depend on the cause and the severity of symptoms. (Research evidence = C; expert opinion = consensus.)

Depression may adversely affect both participation in rehabilitation and long-term outcomes and may compound cognitive dysfunction (Bolla-Wilson, Robinson, Starkstein, et al., 1989). Documented effects include a higher 10-year mortality than that of nondepressed patients (Morris, Robinson, Andrzejewski, et al., 1993), longer lengths of stay in inpatient rehabilitation programs (Schubert, Burns, Paras, et al., 1992b), greater disability in ADL (Parikh, Robinson, Lipsey, et al., 1990; Schubert, Taylor, Lee, et al., 1992c), higher rates of discharge to an institution (Cushman, 1988), and lower levels of social activities (Gordon, Hibbard, Egelko, et al., 1985) and sexual functioning (Monga, Lawson, and Inglis, 1986). Fortunately, symptoms tend to resolve spontaneously during recovery; however, they may last for 2 years or more (Morris, Robinson, and Raphael, 1990; Robinson, Bolduc, and Price, 1987).

Effective treatment depends on an accurate diagnosis. The first step is to ensure that the patient is receiving the best possible care for other disabilities and that depressive symptoms are not due to medications (e.g., sedatives) or environmental factors (e.g., interruption of sleep habits or dissatisfaction with rehabilitation). Mild symptoms of depression will often respond to greater attention and encouragement from staff or family, simple changes in the environment, or active participation in therapeutic activities. More severe depression may respond to antidepressant medications or psychotherapy (cognitive, interpersonal, or behavioral). No controlled studies have examined the effectiveness of psychotherapy specifically in patients with depression due to stroke. The effectiveness of medications has been demonstrated in three small randomized controlled trials and is supported by numerous uncontrolled studies (Andersen, Verstergaard, and Lauritzen, 1994; Lipsey, Robinson, Pearlson, et al., 1984; Reding, Orto, Winter, et al., 1986). (For more information, see Table 23.)

Table 23. Evidence on the effectiveness of drug treatment of post-stroke depression

Author, Year, Country | Purpose, Study design Duration of deficits Number of subjects | Outcome measures Maximum followup | Conclusions/Comments
Reding, Orto, Winter, et al. (1986) United States | Examine effectiveness of trazodone in post-stroke depression Triple-blinded RCT Acute deficits N = 27 | ADL (Barthel) F/U at 4 to 5 weeks | Treated group improved more, but results significant only for patients with a positive dexamethasone suppression test.
Lipsey, Robinson, Pearlson, et al. (1984) United States | Examine effectiveness of nortriptyline in post-stroke depression Double-blinded RCT Acute deficits N = 34 | Hamilton Depression Studies (HDS) Zung Depression Scale (ZDS) Present State Examination (PSE) Mini-Mental State (MMS) John Hopkins Functioning Inventory (JHFI) Social Ties Checklist (STC) F/U at 6 weeks | Treated group improved more on depression scales but not in functional abilities.

Note: ADL = activities of daily living, F/U = followup, RCT = randomized controlled trial.

Side effects from antidepressant medications are common in patients with strokes. When medications are used, drugs with favorable side-effect profiles are preferable. Alternatives include serotonin reuptake inhibitors and tricyclic antidepressants. Initial doses should be small and side effects should be closely monitored. Patients with major depression usually require treatment with medication. Regardless of which treatment modality is chosen, the patient's response should be assessed and treatments adjusted accordingly.

Evidence supporting methods of diagnosing and treating depression has been well documented in the literature and is summarized in an AHCPR-sponsored guideline on depression (Depression Guideline Panel, 1993) and in a review article (Starkstein and Robinson, 1994).

### Other Emotional Reactions to Stroke

Emotional disturbances such as apathy, mania, delusions, hallucinations, personality changes, and obsessive-compulsive disorders occur in patients with strokes (but are relatively rare). Emotional responses such as grief or anger over the losses of function due to stroke, anxiety, altered body image and self-esteem, emotional lability, and impulsive behaviors are more common. Diagnosis depends primarily on the clinical interview. Recognition of these problems is important so that precautions can be taken to protect patient safety, and treatment with behavioral approaches or medications can be given. The effectiveness of treatment has been well demonstrated for pathologic laughing and crying after stroke (Robinson, Parikh, Lipsey, et al., 1993).

## Treating Speech and Language Disorders

### Introduction

Speech or language disorders occur in as many as 40 percent of patients with strokes. Rapid spontaneous improvement is common; however, persisting problems may have pervasive consequences for the quality of a person's life, ranging from loss of employability to feelings of social isolation. Reactive depression, withdrawal, disruption of family roles, and loss of income are common.

Assessment of speech and language function is discussed in Chapter 3. Accurate documentation of deficits is required to guide the choice of treatments. For this reason, all patients with speech and language disorders should have a hearing evaluation, and the use of standardized tests ">(see Attachment 9) is strongly recommended.

### Aphasia

Recommendation: Patients with aphasia should be offered treatment targeted at the identified language retrieval or comprehension deficits and aimed at improving functional communication. (Research evidence = C; expert opinion = consensus.)

Goals of treatment for aphasia are to (1) reinstate (remediate) the aphasic patient's ability to speak, comprehend, read, and write; (2) assist the patient in developing strategies that compensate for or circumvent language problems; (3) address associated psychological problems that compromise the quality of life of aphasic patients and their families; and (4) help the family and involved others to communicate with the patient.

A large number of techniques are used by speech-language pathologists. The following interventions have been studied experimentally or have been developed and tested in at least one treatment or treatment comparison study.

- Traditional stimulus-response modality-specific treatments and drills such as Language Oriented Treatment (LOT) (Shewan and Bandur, 1982), direct stimulus-response treatment (Wertz, Collins, Weiss, et al., 1981; Wertz, Weiss, Aten, et al., 1986), and Melodic Intonation Therapy (Therapeutics and Technology Assessment Subcommittee of the American Academy of Neurology, 1994).
- Methods that work on deficits that underlie language disorders such as perseveration and difficulties in symbol use, including Treatment of Aphasic Perseveration (TAP) (Helm-Estabrooks, Emery, and Albert, 1987) and Visual Action Therapy (VAT) (Helm-Estabrooks, Fitzpatrick, and Barresi, 1982).
- Methods that teach compensatory strategies designed to circumvent language deficits, such as Conversational Coaching (Holland, 1980) and Promoting Aphasic Communicative Effectiveness (Davis and Wilcox, 1985).
- Methods that teach alternative and augmentative communication systems to aphasic adults. The best example is C-Vic (Weinrich, Steele, Carlson, et al., 1989).
- Developmental methods that represent attempts to apply emerging concepts from cognitive neuropsychology to the remediation of aphasia (Byng, 1988; Mitchum, Handiges, and Berndt, 1993).
- Programmatic approaches that combine features of all of the above. An illustration is furnished by Springer, Glindemann, and Huber (1991).

Treatment for aphasia can be integrated with treatments for sensorimotor or cognitive deficits or can be provided separately. Treatment should involve family and caregivers so that effective communication can be reestablished, and family members can be instructed in communication techniques.

Evidence from controlled trials on the effectiveness of treatment for aphasia is not conclusive (see Table 24). Some studies indicate benefit (Wertz, Collins, Weiss, et al., 1981; Wertz, Weiss, Aten, et al., 1986), while other studies fail to document sustained benefits (Hartman and Landau, 1987; Lincoln, McGuirk, Mulley, et al., 1984). To date, no study has examined the relationship between treatment effectiveness and the characteristics of the patient or tested the benefits of treatments specifically tailored to the patient's deficits. Treatment by trained volunteers appears to be equally effective as that by speech and language professionals, and results appear to be unaffected by delaying treatment (Wertz, Weiss, Aten, et al., 1986).

Table 24. Evidence on the effectiveness of treatment of speech and language deficits

Author, Year, Country | Purpose, Study design Duration of deficits Number of subjects | Outcome measures Maximum followup | Conclusions/Comments
Poeck, Huber, and Willmes (1989) West Germany | Compare intense language treatment to spontaneous recovery and examine benefits of treatment 12 months post-stroke Non-RCT (unselected retrospective control group) Acute and chronic deficits N = 229 | Aachen Aphasia Test 8 week post-test | Differences significant in patients treated < 4 months after strokes, but not in patients treated later. 68% of chronic patients (> 12 months after stroke) improved significantly.
Hartman and Landau (1987) United States | Compare traditional language therapy to supportive counseling RCT Acute deficits N = 60 | PICA change score F/U until 10 months post-stroke | No significant differences between treatment groups.
Wertz, Weiss, Aten, et al. (1986) United States | Compare treatment to no treatment and treatment by speech and language professionals to trained volunteers; examine effects of delaying treatment RCT Acute deficits N = 121 | PICA scores F/U until 24 weeks | Differences between treatment and no treatment groups were significant, but not those between home treatment and no treatment, home treatment and clinic treatment, or earlier and deferred treatment.
Lincoln, McGuirk, Mulley, et al. (1984) United Kingdom | Compare speech treatment to natural recovery RCT, but analysis confined to patients who completed 24 weeks of treatment and matched controls Acute deficits N = 191 (327 randomized, but only 191 completed analysis) | PICA Functional Communication Profile F/U to 34 weeks post-stroke | No significant differences among groups. Only 27 subjects received > 36 treatment sessions.
Shewan and Kertesz (1984) N/A | Compare treatment by speech-language pathologists (SLPs) to treatment by trained volunteers; compare treatment to no treatment Partial RCT--random assignment to treatment groups; self-selected control group Acute deficits N = 100 | Western Aphasia Battery Auditory Comprehension Test for Sentences F/U until 1 year | Significantly greater improvement in treated group than (noncomparable) controls. No significant differences between treatment by SLP and trained volunteers or between language-oriented treatment and stimulus-facilitation treatment by SLP.
Wertz, Collins, Weiss, et al. (1981) United States | Compare individual with group treatment RCT Acute deficits N = 67 | PICA scores Token Test Word Fluency Test Colored Progressive Matrices Informant's rating Conversational rating F/U until 44 weeks | Significant differences favored individual for some PICA subtests but not other outcome measures.
Basso, Capitani, and Vignolo (1979) N/A | Compare treatment to spontaneous recovery Non-RCT Mixed acute and chronic deficits N = 281 | Standard language exam F/U until 6 months | Treated patients improved more. Increased time post-onset and aphasia severity negatively associated with improvement.
Butfield and Zangwill (1946) N/A | Examine treatment outcomes Observational study Mixed acute and chronic deficits N = 65 | Clinical staff opinion, testing, and clinical records Varied F/U | Patients with less severe aphasia improved more. 78% of subjects improved with treatment. Study primarily of historic interest.

Note: ADL = activities of daily living, F/U = followup, PICA = Porch Index of Communicative Abilities, RCT = randomized controlled trial.

### Right Hemisphere Communication Disorders

Goals of treatment for right hemisphere communication disorders are to increase awareness of deficits, reinstate communicative behaviors that have been disrupted, and provide compensatory techniques when restoration is not possible. Treatments are directed at the organization of language, its use in context, learning to interpret figurative language, and learning to use language in problem solving. Because right hemisphere language disorders are complex and their treatment is a relatively new field, the effectiveness of treatment has not been fully evaluated.

### Dysarthria and Apraxia of Speech

Goals of treatment for dysarthria and apraxia of speech are to reinstate normal intelligibility to the dysarthric or apraxic person's speech or to use compensatory strategies or devices when intelligibility remains limited. Apraxia of speech, dysarthria, and aphasia often coexist. In such cases, the goal is to determine the contribution of each type of deficit to problems in functional communication and to develop an integrated treatment plan.

For dysarthric speakers, indirect treatment methods include sensory stimulation, exercises intended to strengthen speech musculature or modify muscle tone, modifying positioning and posture for speech, and improving respiratory capacity and efficiency. Direct methods include helping dysarthric speakers to produce speech under carefully arranged and controlled conditions. Because speech production typically encompasses respiration, phonation, resonation, articulation, and prosody, each may be the target of direct manipulation and modification.

Treatment for apraxia of speech focuses on the articulatory aspect of speech production. Emphasis is on relearning articulatory patterns and sequences of gestures, often hierarchically arranged to begin at relatively automatic levels and progress to more purposive communication. Intra- and intersystemic reorganization of the speech act is a programmatic approach based on learning to intone speech that has been used successfully in apractic speakers (Rosenbek, 1985; Wertz, 1984). Evidence supporting the effectiveness of treatments for dysarthria and apraxia of speech are limited to single-subject studies and case series.

Severely impaired dysarthric and apraxic speakers may benefit from alternative forms of communication or augmentative devices such as communication boards and books, pacing boards, and sophisticated electronic communication devices.

## Discharge

### Indications for Discharge

Recommendation: Discharge from a rehabilitation program should occur when reasonable treatment goals have been achieved. Absence of progress on two successive evaluations should lead to reconsideration of the treatment regimen or the appropriateness of the current setting. (Research evidence = NA; expert opinion = consensus.)

The term "reasonable treatment goals" is used to emphasize the importance of not underestimating or overestimating the patient's capabilities. When reasonable goals have been achieved, the patient is better served by moving to the next stage of recovery.

Lack of objective evidence of progress at two successive evaluations (i.e., over a period of 2 weeks in an intense program and 4 weeks in a less intense program) often indicates that a functional ceiling has been reached. Unless there is a good reason for the plateau in functional gain, transfer to a different level of care may be in the patient's best interests, and may also represent cost-effective use of rehabilitation resources.

### Assessment Prior to Discharge

Recommendation: Assessment prior to discharge should include the patient's functional status, the proposed living environment, the adequacy of support by family or involved others, financial resources, and the availability of social and community supports. (Research evidence = NA; expert opinion = strong consensus.)

The predischarge assessment provides essential information for discharge planning, both about the patient and about the environment to which the patient will return. The assessment also provides a summary measure of gains achieved during the rehabilitation program and a baseline for monitoring subsequent progress. Performance of both basic and instrumental ADL is an important component of the assessment.

### Discharge Planning

#### Overview

Recommendation: Discharge planning should begin at the time of admission; should be a systematic, interdisciplinary process, coordinated by a single health provider; should intimately involve the patient and family; and should include assessment of the patient's living environment, family/caregiver support, disability entitlements, and potential for vocational rehabilitation. To the maximum extent possible, all decisions should reflect a consensus among the patient, family/caregivers, and rehabilitation team. (Research evidence = NA; expert opinion = strong consensus.)

Discharge from a rehabilitation program marks a critical point on the trajectory of post-stroke recovery and an important transition to new challenges. Discharge planning should begin on the day of admission to a rehabilitation program. At this time, initial information is obtained on the extent of family or caregiver support available and the potential places of residence after rehabilitation (in the case of inpatient programs). Goals of discharge planning are to:

- Identify a safe place of residence.
- Ensure that the patient and family/caregiver are adequately trained in essential skills.
- Arrange for continued medical care.
- Arrange for continued rehabilitation services.
- Arrange for needed community services.

#### Recommending a Safe Place of Residence.

The main considerations in selecting a place of residence are the patient's disabilities, a realistic assessment of the family/caregiver's capabilities, and safety (all in the context of patient and family preferences). Safety refers both to personal safety (ability to satisfy daily needs with minimal physical and emotional risk) and medical safety (prevention of complications and access to medical services in case of emergency). The goal is to capitalize on patient, family, and community strengths; and to reach a consensus decision that effectively balances fulfillment of patient needs and patient and family values and preferences. Patient, family, and community contextual factors are very important considerations (see Table 6 in Chapter 3).

A therapeutic leave of absence (LOA) for the patient and a home visit by a therapist can greatly facilitate transition to an independent or assisted living situation in patients with moderate to severe residual disabilities. The LOA allows the patient and family to test their abilities and identify problem areas that require more attention before discharge. The home visit permits the therapist to identify safety hazards, rehearse the patient's daily routine, and assess the accessibility of community facilities typically used by the patient (e. g., a grocery store, church, or recreation center). When a home visit is not feasible, the strengths and limitations of the home environment need to be carefully reviewed during discussions with the patient and the family or other caregivers.

Minor structural problems at the chosen place of residence can be corrected by relocating storage of objects (e.g., clothing, grooming supplies, kitchen equipment and supplies, hobby equipment and supplies) or removing scatter rugs or obstacles to ambulation. Other problems may require purchase of equipment or alterations such as installation of a bath bench, toilet rails, or grab bars for the bath area, or widening doors to allow wheelchair access. Needs for major alterations (e.g., an elevator to enter the home or permit access to the second floor), strategies for improving access to community resources, and plans for action in case of emergency also can be reviewed.

Another important consideration in choosing a place of residence is making a realistic assessment of the caregiver support that will be available to the stroke survivor. This assessment can be aided by examining the contextual factors listed in Table 6 (see Chapter 3) and, where applicable, by repeating administration of the Family Assessment Device (see Attachment 12) to identify any interim changes that may affect the adequacy of support or indicate the need for family counseling. One cannot assume that a spouse, child, or friend with whom the patient was living before the stroke will be able or willing to provide needed support. For example, an elderly spouse who is in poor health may not be able to tolerate the physical and emotional strain of caregiving, and adult children may be unable or unwilling to take on caregiver responsibilities. If adequate support is not available at home, it may be necessary to look for an alternative place of residence. The role of caregiver and ways of assisting caregivers are discussed in the next chapter.

#### Patient and Family Education

Education and training of the patient and family prior to discharge should emphasize issues that will be most relevant during transition. These need to be individualized to the patient but may include:

- Preventing recurrent stroke.
- Signs and symptoms of potential complications.
- Signs and symptoms of psychological dysfunction.
- Medication taking.
- Techniques required for specific tasks (e.g., transfers, personal hygiene, and dressing).
- Swallowing techniques for the dysphagic patient.
- Nutrition and hydration.
- Care of an indwelling bladder catheter.
- Skin care.
- Use of a feeding tube.
- Home exercises.
- Sexual functioning.
- Recreational and vocational or volunteer pursuits.
- Driving a car.

Attention to family/caregiver education and counseling has been shown to increase knowledge, help stabilize some aspects of family functioning (Evans, Matlock, Bishop, et al., 1988), and contribute to the maintenance of rehabilitation gains (Garraway, Walton, Akhtar, et al., 1981; Strand, Asplund, Eriksson, et al., 1985).

#### Continuity of Care

All patients will require continued medical care after discharge from a rehabilitation program, and many patients will require continued rehabilitation services. Discharge planning includes making explicit arrangements for these services and ensuring that full information on the patient's medical and neurological status, the patient's responses to rehabilitation interventions, and recommendations for future medical and rehabilitation treatments are transmitted to future providers at the time of discharge. Effective communication will help avoid gaps in care and lay the groundwork for future progress. As discussed in the next chapter, a single health care provider should be in overall charge of coordinating medical and other services after discharge.

#### Community Services

Home care and other services from community agencies can help to supplement or substitute for services provided by family or caregivers. Some sources of community services are discussed in Chapter 7. Stroke groups, if available, may be particularly helpful to the patient and family. Every rehabilitation facility should maintain an up-to-date inventory of local, regional, and national services. These should be reviewed with the patient and family prior to discharge, and linkages should be established for services that are both needed and desired.