# Screening for Rehabilitation and Choice of a Setting

## Introduction

Many people who have had a stroke require assistance in adjusting to disabilities after stroke, and some are candidates for a rehabilitation program. The need for rehabilitation should be considered as soon as the patient's medical and neurological status has stabilized.

Figure 4 summarizes the process of reaching a rehabilitation decision. This decision is based primarily on information gathered during a screening examination. The overall goal is to achieve the best possible match between the needs of the patient and the capabilities of rehabilitation programs available in a community. Limited options for rehabilitation in some communities, particularly in rural areas, may restrict choices.

Framework for rehabilitation decisions

Recommendations in this chapter are focused on the initial rehabilitation decision following an acute hospitalization for a stroke. However, they also apply to changes in the rehabilitation setting or the level of care during later stages of recovery. The recommendations are based almost entirely on the judgments of experts in rehabilitation. Although the available evidence Table 10 suggests that rehabilitation is beneficial to some patients, no study has clearly demonstrated the superiority of one type of program or rehabilitation setting over another or specifically identified the characteristics of patients most likely to benefit.

Table 10. Evidence on the effectiveness of rehabilitation in different types of settings

Author, Year, Country | Purpose, Study design Duration of deficits Number of subjects | Outcome measures Maximum followup | Conclusions/Comments
Young and Forster (1991 and 1992) United Kingdom | Compare day hospital with home physiotherapy RCT stratified by time since onset and disability level Acute deficits N=125 | Functional ambulation ADL (Barthel) Motor Club Assessment Frenchay Activities Index Nottingham Health Profile General Health Questionnaire F/U until 6 months | Home physiotherapy significantly more effective and resource efficient.
Wade, Collen, Robb et al.(1992) United Kingdom | Test whether outpatient PT improves mobility in chronic stroke patients RCT with crossover Chronic deficits N=9 | Motricity Index Functional Ambulation Categories Rivermead Motor Assessment Frenchay Activities Index Gait speed Rivermead Mobility Index Nottingham Extended ADL Index Hospital Anxiety and Depression Scale Nine-hole peg test | Outpatient PT increases gait speed in chronic stroke patients, but benefits decline after therapy stopped.
Wade, Langton-Hewer, Skilbeck, et al. (1985) United Kingdom | Examine value of home-care services for stroke patients Non-RCT Acute deficits N=857 | ADL (Barthel) Frenchay Activities Index Wakefield Depression Inventory General Health Questionnaire (for caregivers) F/U until 6 months | No difference in functional recovery or stress on caregivers.
Sivenius, Pyorala, Heinonen, et al. (1985) Finland | Compare intensive rehab (IT) to conventional rehab in an acute care hospital RCT Acute deficits N=95 | Motor function ADL (Lehmann) Mortality F/U until 1 year | Motor function score better in IT group until 1 year and ADL score until 3 months. No differences in mortality. Differences in baseline function raise questions about the success of randomization.
Tucker, Davison, and Ogle (1984) New Zealand | Examine benefits of day hospital rehabilitation RCT NA N=120 | ADL (Northwick Park) Zung Depression Scale F/U until 5 months | Day hospital group improved more on ADL at 6 weeks and depression score up to 5 months, but cost higher than usual care. No significant differences in outcomes.
Smith, Goldenberg, Ashburn, et al. (1981) United Kingdom | Test whether more intensive OP rehab improves outcomes RCT Acute deficits N=133 | Mortality ADL F/U until 12 months | Graded response of ADL to intensity of treatment with significant differences between intense rehab and no formal treatment up to 1 year.
Feigenson, Gitlow, and Greenberg (1979) United States | Test whether a stroke-dedicated rehab unit in a facility achieves better outcomes than multiple diagnosis rehab units Retrospective non-RCT Acute deficits N=667 | Ambulation ADL Length of stay Discharged home Mortality F/U until discharge | Functional outcomes similar despite more severe neurological deficits in stroke-only unit at the time of admission.

Note: ADL = activities of daily living, F/U = followup, IT = intensive rehabilitation therapy, NA = not available, OP = outpatient, PT = physical therapy, RCT = randomized controlled trial, Rehab = rehabilitation.

## Screening for Rehabilitation

Recommendation: Screening for possible admission to a rehabilitation program should be performed as soon as the patient's neurological and medical condition permits. The individual(s) performing the screening examination should be experienced in stroke rehabilitation and preferably should have no direct financial interest in the referral decision. All screening information should be summarized in the acute medical record and provided to the rehabilitation setting at the time of referral. (Research evidence = NA; expert opinion = strong consensus.)

The purpose of the screening examination is to identify patients who need rehabilitation and to select the best possible rehabilitation setting. Patients will not require a complete screening examination if they are clearly not candidates for rehabilitation. This is because they have either recovered completely or they are too disabled by paralyses, cognitive problems, or comorbid conditions to participate gainfully.

The screening examination should be sensitive to the concerns of patient and family and to their needs for understanding, caring, and support. This implies that screening should cast a relatively broad net in an effort to identify all patients who are likely to benefit from rehabilitation. Subsequent detailed assessment by the rehabilitation program can then validate the appropriateness of the referral. Also, screening must be practical in terms of the time, effort, and skills required.

Areas of information covered by the screening examination are listed in Table 11. This examination can be completed in 1 hour or less by a well-trained rehabilitation clinician if the medical record contains a complete and current description of neurological deficits, comorbid diseases, and functional health patterns.

Table 11. Screening for rehabilitation

- Current clinical status; - Neurological deficits.; - Comorbid diseases.; - Functional health patterns: nutrition and hydration, ability to swallow, bowel and bladder continence, skin integrity, activity tolerance, sleep patterns.; - Special emphases; - Functional status prior to stroke.; - Current functional deficits.; - Mental status and ability to learn.; - Emotional status and motivation to participate in rehabilitation.; - Functional communication.; - Physical activity endurance.; - Social and environmental factors; - Presence of spouse or significant other.; - Previous living situation.; - Ethnicity and native language.; - Adjustment of patient and family to stroke.; - Patient and family preferences for and expectations of rehabilitation.; - Extent of support by family or involved others (relationships, number, health, availability).; - Characteristics of potential postdischarge environments.; - Standardized instruments; - Stroke deficit scale.; - Measure of disability (ADL).; - Mental status screening test.

Note: ADL = activities of daily living.

The patient's medical stability and the nature and extent of functional limitations are the most important determinants of the need for rehabilitation and the appropriate choice of a rehabilitation program or service. The functional status and degree of independence prior to the stroke provide reasonable upper bounds on expectations for rehabilitation.

The patient's ability to tolerate the physical activity required by rehabilitation should be carefully evaluated. Cardiopulmonary endurance and the muscle strength of uninvolved limbs must be sufficient to permit training in mobility and ADL. Major orthopedic problems such as severe arthritis may also limit rehabilitation. Evaluation of patients with compromised physical activity endurance should attempt to distinguish cardiopulmonary limitations due to deconditioning from those due to major cardiovascular or pulmonary comorbidity.

Information on social, cultural, economic, and environmental factors is best obtained through interviews with the patient and family. Expectations for rehabilitation and preferences for choice of setting should be explored, since rehabilitation is more likely to be successful if the patient and family are fully supportive. The program choice may also be influenced by the home environment--whether the structural characteristics of the home permit rehabilitation to take place there or will provide a suitable residence after rehabilitation. The availability of family members or involved others to participate in rehabilitation and to provide support at home are especially important.

Standardized instruments are recommended to document levels of neurological impairments and disabilities. An updated assessment on the National Institutes of Health Stroke Scale or the Canadian Neurological Scale used during acute care (see Attachment 2) serves as a benchmark for assessing future neurological improvements. Use of a disability (ADL) scale (see Attachment 4) permits reliable documentation of the performance of basic ADL such as mobility, dressing, grooming, eating, and toileting. The Functional Independence Measure (FIM) has the advantage of including measures of cognitive function, communication, and social functioning. A mental status screening test (see Attachment 5) is useful to document cognitive deficits that may not be readily evident during routine neurological examinations.

Because of the complexity of issues involved in rehabilitation decisions, screening should be performed (whenever possible) by a medically trained person with specialized training in stroke rehabilitation and in the reliable administration of the recommended standardized instruments. To minimize the potential for bias, the screening clinician ideally should have no direct financial interest in the referral decision. Decisions based on incomplete information or on triage relying solely on information from referring physicians not trained in rehabilitation are discouraged.

Additional time and effort spent on a thorough screening examination will better serve the interests of the patient and family and will also lead to more cost-effective use of stroke rehabilitation resources.

## Rehabilitation Programs and Settings

Stroke rehabilitation following discharge from acute care can be conducted in inpatient rehabilitation hospitals or rehabilitation units in acute care hospitals, nursing facilities, the patient's home, or outpatient facilities. The capabilities typical of each type of setting will be discussed.

### Hospital Inpatient Rehabilitation

Programs of rehabilitation hospitals or rehabilitation units in acute care hospitals are staffed by the full range of rehabilitation professionals--nurses, physical and occupational therapists, speech-language pathologists, psychologists, social workers, recreational therapists, and physicians. A physician skilled in rehabilitation is available 24 hours a day. An interdisciplinary team drawing on these professionals provides a comprehensive rehabilitation program for each patient. Team conferences are held at least weekly to establish rehabilitation goals and develop a rehabilitation plan, assess patient progress, identify barriers or complications and revise the rehabilitation goals or plan accordingly, and develop a plan for discharge or transfer to another type of rehabilitation program (National Association of Rehabilitation Facilities, 1988).

Hospital-level rehabilitation is usually more intense and comprehensive than rehabilitation in other settings and requires greater physical and mental effort from the patient.

### Rehabilitation in Nursing Facilities

Rehabilitation programs in nursing facilities vary widely in their capabilities. Traditionally, nursing homes have provided supportive care and low-level rehabilitation services. More recently, however, some nursing facilities have developed coordinated rehabilitation programs that are similar to, though usually less intense than, hospital programs. Physician coverage in nursing facilities varies.

Nursing facilities may be either hospital based or community based. Hospital-based nursing facilities are designed primarily for patients who have the potential to improve enough during 2 or 3 weeks of treatment to become suitable candidates for inpatient hospital, home, or outpatient rehabilitation. Community-based nursing facilities run the full gamut of comprehensiveness and intensity of services. Some offer comprehensive programs providing a thorough evaluation at the time of admission, medical management by a qualified rehabilitation physician, 24-hour nursing care, and interdisciplinary treatment. At the other end of the spectrum are nursing facilities with limited rehabilitation capabilities that provide physical therapy and occupational therapy for up to 1 hour a day, 5 days per week--are staffed with nurses who may or may not have special training in rehabilitation--and are usually covered by physicians with no specific training in rehabilitation.

This diversity among nursing facility programs underscores the need for referring clinicians to inform themselves about the capabilities of individual programs.

### Outpatient Rehabilitation

Outpatient rehabilitation is provided by hospital outpatient departments and freestanding outpatient facilities. These facilities can provide either a comprehensive rehabilitation program or individual rehabilitation services. Intensity may range from occasional visits to three or four visits per week. Advantages of outpatient programs are the access they permit to an interdisciplinary program, the availability of rehabilitation equipment, and the opportunity for social contact and peer support while the patient lives at home. The availability of transportation is a prerequisite.

Day hospital programs are similar to outpatient programs though frequently more intense. The patient spends several hours, 3 to 5 days a week, in a typical day hospital program. Availability of transportation is a prerequisite for both outpatient and day hospital programs.

### Home Rehabilitation

Home rehabilitation programs are expanding their capabilities. Most programs are designed for patients who are medically stable and require only intermittent contact with physical or occupational therapy or nursing services. However, some home health agencies provide the full scope of services including nursing, physical therapy, occupational therapy, speech therapy, medical social services and personal care services, as well as rehabilitation nursing and mental health nursing. Recently, some home rehabilitation programs have been developed that provide comprehensive services including 24-hour coverage by physicians (Portnow, Kline, Daly, et al., 1991). The usefulness and cost effectiveness of these programs have not been fully evaluated. In programs approved by Medicare, a physician and an interdisciplinary team develop the treatment plan and monitor medical stability.

Advantages of home care programs are that rehabilitation takes place in the same environment where the skills learned will be applied, and that many patients function better in a familiar environment. Disadvantages include an increased burden on caregivers, less availability of physician monitoring, absence of peer support from fellow patients, and limited availability in the home of equipment used in facility-based inpatient or outpatient rehabilitation programs. Home rehabilitation may be the only choice for patients who would be suitable for outpatient rehabilitation but lack transportation. For some patients, a combination of outpatient and home rehabilitation may be beneficial.

### The Need for Accurate Program Information

Recommendation: Rehabilitation programs should maintain up-to-date information on staffing patterns, services offered, and quality indicators and outcomes and should make this information widely available to health care providers, medical facilities, and the public. Health care providers and hospitals who refer patients to rehabilitation programs should be knowledgeable about the capabilities of programs in their communities. (Research evidence = NA; expert opinion = consensus.)

Rehabilitation decisions will better serve the needs of patients if they are based on objective information on the capabilities and actual performance of rehabilitation facilities. In spite of efforts to establish standards, the capabilities of programs in each type of setting vary widely.

Freestanding rehabilitation hospitals, rehabilitation units of acute care hospitals, and nursing facility programs that have been certified by the Commission on Accreditation of Rehabilitation Facilities (CARF) 1 and the Joint Commission on Accreditation of Healthcare Organizations (JCAHO) 2 are required to meet specific structural, staffing, and program standards. However, the ability to satisfy these accreditation standards does not guarantee uniform capabilities and quality of care.

[1] The CARF address for correspondence is 101 North Wilmot Road, Suite 500, Tucson, AZ 85711. Telephone: (602) 748-1212.][2] JCAHO address for correspondence is 1 Renaissance Boulevard, Oak Brook Terrace, IL 61081. Telephone: (708) 916-5600.

Rehabilitation hospitals or nursing facility programs that have not been certified by CARF or JCAHO, outpatient departments, and home care agencies currently lack uniform standards. Local initiatives to obtain information about these programs will be especially important until regional or national standards can be developed and implemented. [3]

[3] CARF has proposed a new classification scheme for rehabilitation that includes a broadened range of nursing facility programs. CARF also plans to develop accreditation for home programs.

## Definitions

The recommendations in this chapter relating patient characteristics to decisions on the appropriate type of rehabilitation setting use the following definitions.

### Medical Stability

Medical stability is an important consideration affecting the patient's readiness for rehabilitation and the choice of rehabilitation setting. Degrees of medical stability are defined as follows:

- Stable.
- Patient is afebrile, has stable vital signs, and has had no important changes in medical conditions, nor required changes in treatments within the preceding 48 hours. Neurological deficits are unchanged or improving. The patient can take adequate nutrition orally or an enteral route for nutrition and hydration has been established.
- Moderately stable.
- One or more medical problems has required a change in medications within the preceding 48 hours, but symptoms or clinical findings have not changed significantly. An adequate route for nutrition and hydration has not been established. Neurological deficits are unchanged or improving.
- Unstable.
- Patient has undiagnosed or inadequately treated cardiac arrhythmia, congestive heart failure, or other condition that requires the diagnostic or treatment capabilities of an acute care hospital. The condition may be life threatening, may lead to severe morbidity if not promptly treated, or will interfere with rehabilitation. Neurological deficits or state of consciousness have fluctuated within the preceding 48 hours.

### Functional Disabilities

The functions considered here are mobility (e.g., getting out of bed, walking or climbing stairs, using a wheelchair) and performance of basic ADL (e.g., eating, grooming, and dressing). Levels of disability are classified as:

- Complete independence
- . Ability to perform the activity safely and within a reasonable period of time with no assistance.
- Modified independence
- . Activity performance requires specialized equipment or takes more than a reasonable time or requires safety precautions, but no helper is needed.
- Supervision or setup
- . Activity requires verbal encouragement or instructions or assistance with preparation (such as opening containers or applying toothpaste to a brush), but no contact assistance.
- Minimal contact assistance
- . Ability to perform 75 percent or more of the activity unassisted; physical assistance required for the remainder.
- Moderate assistance
- . Ability to perform 50 to 74 percent of the activity unassisted; physical assistance required for the remainder.
- Maximal assistance
- . Ability to perform 25 to 49 percent of the activity unassisted; physical assistance required for the remainder.
- Total assistance
- . Ability to perform less than 25 percent of the activity unassisted; physical assistance required for the remainder.

### Mental Status

Mental status affects the patient's ability to learn and retain the lessons being taught during rehabilitation. Mental status includes the degree of alertness, orientation, memory, control of behavior, and problem-solving ability. Levels of impairment are classified as:

- Normal or minimal deficit
- . Patient is alert and fully oriented, performs well on simple tests of recent memory, is consistently in control of behavior and emotions, and is easily able to follow 2-step directions.
- Moderate deficit
- . Patient is intermittently confused in time or place, or recent memory is impaired but patient is able to retain simple messages after multiple repetitions, or patient makes frequent mistakes in following 2-step directions.
- Severe deficit
- . Patient is consistently disoriented in time and place, or recent memory is severely impaired, or patient is unable to follow 2-step directions.

### Physical Activity Endurance

The physical demands of rehabilitation are substantial, particularly in light of the increased effort required by the presence of hemiparesis. Physical endurance is categorized by the time a person is able to engage in physically demanding activity equivalent to that required during active rehabilitation interventions:

- 3 or more hours of physical activity per day.
- 1 to 3 hours.
- Less than 1 hour.

A threshold criterion for admission to any rehabilitation program is defined as the ability to sit supported for at least 1 hour and at least some ability to participate actively in rehabilitation interventions.

### Caregiver Support

The patient's previous living environment and the availability of family or friends to provide assistance after discharge may influence rehabilitation decisions. Assessing the adequacy of caregiver support requires a qualitative judgment by the screening clinician.

## Rehabilitation Decisions

### The Need for Consensus

Recommendation: To the maximum extent possible, decisions about entry into a rehabilitation program should reflect a consensus among the patient, family or involved others, physician (in collaboration with care providers), and the rehabilitation program. (Research evidence = NA; expert opinion = strong consensus.)

Rehabilitation is fundamentally a patient-centered process that also intimately involves the family (using the term "family" broadly to include other involved persons as well). This requires the full support and active participation of the patient and family. Hence, rehabilitation decisions need to be mutually acceptable to all involved parties. Patient and family education about stroke rehabilitation, its goals and procedures, available programs, and their outcomes provide important inputs. Sensitivity to language problems and to cultural differences is important. In making a recommendation about rehabilitation to the patient and family, clinicians need to explain clearly the reasons for the recommendation and listen carefully to any concerns the patient or family have that may dictate a different choice. For example, the program that is best from a clinical point of view might be unaffordable, might be located too far away for frequent family visits, or might have characteristics or sponsorship with which the family is not comfortable.

### Threshold Criteria for Admission to a Rehabilitation Program

Recommendation: The most important determinants of the need for a rehabilitation program are the patient's type/types and severity/ severities of impairments and functional disabilities, the ability to learn, and physical activity endurance. (Research evidence = NA; expert opinion = strong consensus.)

Threshold patient characteristics for entry into any active rehabilitation program are shown in Figure 5. Terms were defined earlier in the chapter. Threshold criteria are (1) patient is medically stable or moderately stable, (2) patient has one or more persistent disabilities, (3) patient is able to learn, and (4) patient has enough physical activity endurance to sit supported for at least 1 hour a day and to participate actively in rehabilitation (physical endurance less than this minimal level indicates that rehabilitation services at home or in a supportive living setting would be a better choice).

Patients who are too debilitated to participate in an active rehabilitation program may benefit from a brief interdisciplinary program designed to educate the family and provide "hands-on" training in the skills needed to maintain a severely disabled patient at home. Objectives of such a program are to ensure that the family has a thorough understanding of the patient's impairments, the risks they entail, and opportunities and techniques for maximizing function. This type of program can be conducted in a rehabilitation facility (hospital or nursing facility), a day program, or at home. A facility-based program makes it easier to involve multiple professional disciplines and provide access to needed equipment; a home program has the advantage of enabling the training to be adapted to the actual home environment.

Recommendation: Admission to an interdisciplinary rehabilitation program should generally be limited to patients with disabilities in two or more of the following areas of function: mobility, performance of the basic activities of daily living, bowel or bladder control, cognition, emotional functioning, pain management, swallowing, and communication. (Research evidence = NA; expert opinion = consensus.)

An isolated disability can usually be treated by services rendered by an individual rehabilitation discipline and does not require the involvement of an interdisciplinary team. Examples would be treatment of isolated motor weakness of the leg or the arm, or treatment of aphasia. The presence of cognitive, emotional, or other problems that increase the complexity of rehabilitation may require an interdisciplinary approach even though physical disabilities are mild.

### The Choice of Rehabilitation Setting

For people who meet the preceding threshold criteria, the selection of setting will depend on the patient's medical stability, level of function, mental status, and physical activity endurance; the adequacy of support by family or involved others; the adequacy of the living environment; and the capabilities of rehabilitation facilities in the community. Strong contextual support often broadens the array of options. The relationships between these factors and the choice of type of rehabilitation program are shown in Figure 5.

Selection of setting for rehabilitation program after hospitalization for acute stroke

[This figure is in two parts, see printed version pages 80 and 81]

[left half of figure]

[right half of figure]

Recommendation: Patients who are medically unstable are generally not suitable for any type of rehabilitation program. Patients who are moderately stable but have complex medical problems that require continuous monitoring are usually better treated in inpatient rehabilitation facilities that not only have 24-hour coverage by physicians and nurses skilled in rehabilitation, but also immediately available consultation services from other medical specialties. (Research evidence = NA; expert opinion = strong consensus.)

Few rehabilitation settings have the capability to manage patients who are acutely ill or medically unstable. Patients who develop acute problems during rehabilitation, including worsening of the stroke or a new stroke, will often require transfer to an acute facility that can adequately treat the problem. An exception would be a rehabilitation program that is so closely linked to an acute care facility that adequate diagnosis and treatment can be provided without transfer. This type of linkage is more likely if the rehabilitation program is located in or adjacent to an acute care hospital.

Inpatient rehabilitation facilities that are certified by CARF and JCAHO are required to have 24-hour coverage by skilled rehabilitation physicians and nurses. Coverage in nursing facilities, even those with "intense" programs, is variable and usually less comprehensive. Intense home programs, while they have skilled rehabilitation physicians and nurses on staff, serve the patient on an intermittent or "on-call" basis. Hence, the patient who requires close observation to detect incipient problems, or frequent adjustment of medications, is better suited for a rehabilitation hospital or unit.

Recommendation: Patients who meet threshold criteria and need moderate to total assistance in mobility or performing basic activities of daily living are candidates for an intense rehabilitation program, if they are able to tolerate 3 or more hours of physical activity each day, or less intense programs if they are not. (Research evidence = C; expert opinion = consensus.)

Evidence suggests, but does not establish, that more intense rehabilitation leads to more rapid improvement and better long-term outcomes than more slowly paced programs (see Table 10). Two controlled studies that involved outpatient therapy found positive relationships between the intensity of therapy and functional outcomes in patients with mild or moderate levels of impairment (Smith, Goldenberg, Ashburn, et al., 1981; ). Similarly, two studies of inpatient rehabilitation found that more intense therapy on specialized units led to better functional outcomes than care on general medical units (Sivenius, Pyorala, Heinonen, et al., 1985; Stevens, Ambler, and Warren, 1984). Only Smith, Goldenberg, Ashburn, et al. (1981), however, clearly separated the intensity of therapy from other differences in treatments that may have influenced outcomes. It is difficult to extrapolate the results of these studies to other patient populations or other rehabilitation settings. Nonetheless, there is an inference that "more is better," at least for patients with moderate levels of disability.

As previously discussed, intense rehabilitation can be provided in an inpatient rehabilitation unit or hospital, selected nursing facilities, or selected home programs. The choice depends on the desired degree of intensity and the patient's medical needs. Even nursing facilities and home care providers with "intense" programs usually do not provide the same level of services as a rehabilitation hospital. The availability and commitment of a caregiver to support the patient and participate in rehabilitation are critical to providing intense home-based rehabilitation.

The choice of rehabilitation program for patients needing moderate to total physical assistance will depend on their ability to tolerate the physical activity required by rehabilitation. Patients who can tolerate 3 or more hours of activity a day, or would be expected to do so within a few days in the program, are candidates for an intense rehabilitation program; while those who tolerate only lower levels of activity are usually better served by more slowly paced programs in a nursing facility, an outpatient facility, or the home.

An important consideration is that the energy costs of a physical activity are directly related to the severity of motor disabilities. Hence, a patient with reduced physical activity endurance but less severe motor disability may be able to tolerate intense therapy, while a patient with similar endurance but a more severe disability may not. Some patients who initially have limited physical endurance will improve sufficiently to permit more intense therapy at a later time.

Recommendation: Patients who meet threshold criteria and require only supervision or minimal assistance in mobility or ADL are usually candidates for home or outpatient rehabilitation if the home environment and support are adequate, or for a nursing facility if they are not. (Research evidence = NA; expert opinion = consensus.)

This recommendation applies to patients who are only mildly disabled but are not able to live independently. Safety as well as performance of the essential ADL are concerns. Some patients who need only minimal assistance may be appropriate for inpatient hospital or nursing facility programs if they have complex, multiple functional deficits from physical and/or cognitive impairments, even if home support is adequate. A relatively brief period of rehabilitation in an inpatient program that is targeted at specific disabilities may be sufficient to permit people to live independently.

Recommendation: Patients who have a mild functional deficit but are able to live independently and manage both basic and more complex activities of daily living may benefit from selected rehabilitation services, but do not require an interdisciplinary rehabilitation program. (Research evidence = NA; expert opinion = consensus.)

People who do not require assistance in ambulation or in performing basic personal care activities may still have difficulty performing more complex activities such as housekeeping, meal preparation, use of public transportation, leisure activities, or returning to work. Furthermore, some people may have communication problems but no motor deficits. Rehabilitation services targeted at problem areas may help to increase independence and improve quality of life for those patients, but an interdisciplinary program is rarely needed. Services can be provided on an outpatient basis or at home if a person has adequate support. If, however, a person does not have adequate support, services can be provided in a nursing facility or other supervised living setting.