# Rehabilitation During Acute Care for Stroke

## Introduction

Stroke rehabilitation begins during the acute hospitalization as soon as the diagnosis of stroke is established and life-threatening problems are under control. Highest priorities are to prevent recurrent stroke, prevent complications, ensure proper management of general health functions, mobilize the patient, and encourage resumption of self-care activities as soon as medically feasible. Emotional support for patient and family during this stressful period and education in the effects of stroke and the objectives of treatment are also extremely important.

This chapter addresses:

- Benefits of acute care on dedicated stroke units.
- Clinical evaluation during acute care.
- Preventing recurrent strokes.
- Managing complications and health functions.
- Early mobilization and resumption of self-care activities.
- Needs for patient and family support and education.
- Discharge planning.

The chapter does not discuss the diagnosis or management of acute stroke; the reader is referred to up-to-date reviews of these subjects in the American Heart Association's statement on Management of Patients with Acute Ischemic Stroke (Adams, Brott, Crowell, et al., 1994); the National Stroke Association's consensus statement on Stroke: the First Six Hours (National Stroke Association, 1993); policy-relevant recommendations for the United Kingdom in the chapter on stroke in Health Care Needs Assessment (Wade, 1994); and reviews by Sandercock and Willems (1992) and Marshall and Mohr (1993).

## Treating the Acute Stroke With Coordinated Interdisciplinary Care

Recommendation: Whenever possible, patients with acute strokes should receive coordinated diagnostic, acute management, preventive, and rehabilitative services. (Research evidence = A; expert opinion = consensus.)

Acute care hospitals vary widely in the expertise of staff in treating stroke and in the availability of rehabilitation services. Some hospitals have acute stroke units or well-staffed neurology or rehabilitation departments and can bring a full range of skills to the bedside of the patient with an acute stroke. Other hospitals have more limited capabilities or need to rely on consultants from other local hospitals.

At a minimum, the attending physician should ensure that physicians and rehabilitation specialists with expertise in stroke are closely involved in the patient's care. Serious consideration should be given to transferring the patient to a hospital with a stroke unit, if one exists in reasonable proximity and services in the admitting hospital are limited.

Acute stroke units are organized to provide coordinated services to patients with strokes and are staffed with specifically trained physicians, nurses, and rehabilitation therapists. Some evidence supports the benefits of treatment on such units (see Table 7). A meta-analysis of controlled trials found reduced mortality for up to a year after stroke in patients treated with comprehensive, coordinated rehabilitation services (Langhorne, Williams, Gilchrist, et al., 1993). Most studies also indicate improved functional outcomes, although differences in the outcome measures used make it difficult to combine results (Langhorne, Williams, Gilchrist, et al., 1993). A recent controlled trial not included in these meta-analyses found that the benefits of stroke units extended to people 75 years of age or over, and were greatest in those with strokes of intermediate severity (Kalra, Dale, and Crome, 1993).

Table 7. Evidence on the effectiveness of stroke units and stroke teams

Author,Year Country | Purpose, Study design Duration of deficits Number of subjects | Outcome measures Maximum followup | Conclusions/Comments
Kalra, Dale, and Crome (1993) United Kingdom | Compare SU to GMW care RCT stratified by risk score Acute deficits N=152 | Mortality Discharged home LOS ADL (Barthel) F/U until hospital discharge | Mortality benefits in SU only for poor-risk group. LOS shorter in SU for intermediate- and poor-risk groups. Improved ADL in SU only for intermediate-risk group.
Indredavik, Bakke, Solberg, et al. (1991) Norway | Compare SU to GMW care RCT Acute deficits N=220 | Discharged home Mortality ADL (Barthel) Neurological score F/U until 1 year | Discharge home, ADL score and neurological score favor SU at 6 weeks and 1 year. Mortality favors SU at 6 weeks.
Strand, Asplund, Eriksson, et al. (1985) Sweden | Compare nonintensive stroke unit to GMW care Non-RCT (bed availability on SU) Acute deficits N=293 | Discharged home Mortality ADL F/U until 1 year | Percent discharged home and ADL at 1 year favor SU. Non-RCT design raises questions about selection bias.
Stevens, Ambler, and Warren (1984) United Kingdom | Compare nonacute stroke rehab ward (SRW) to GMW care RCT Acute deficits N=228 | Mortality Discharged home ADL F/U until 1 year | Nonsignificant differences favor SRW.
Wood-Dauphinee, Shapiro, Bass, et al. (1984) Canada | Compare stroke team care to traditional care at medical unit RCT Acute deficits N=126 | Mortality Motor function ADL (Barthel) F/U until 5 weeks | No significant differences in outcomes.
Garraway, Akhtar, Prescott, et al. (1980) Garraway, Akhtar, Hockey, et al. (1980) Garraway, Akhtar, Smith, et al. (1981) Smith, Garraway, Smith, et al. (1982) United Kingdom | Compare SU to GMW care RCT Acute deficits N=312 | Mortality ADL F/U at ADL F/U at discharge and 1 year | Benefits of SU noted at discharge were not sustained at 1 year. SU patients received earlier PT and OT and more OT.
Feldman, Lee, Unterecker, et al. (1962) United States | Compare inpatient care by PM & R rehabilitation staff to GMW care RCT Acute deficits N=82 | Physical impairment ADL Location after discharge F/U until 1 year | No significant differences in outcomes.

Note: ADL = activities of daily living, F/U = followup, GMW = general medical ward, LOS = length of stay, OT = occupational therapy, PM & R = physical medicine and rehabilitation, PT = physical therapy, RCT = randomized controlled trial, SU = stroke unit

Studies of the use of stroke teams to supplement care on general medical wards have yielded less conclusive results (Feldman, Lee, Unterecker, et al., 1962; Wood-Dauphinee, Shapiro, Bass, et al., 1984) Table 7

The reasons for the favorable effects of stroke units are not known. Possibilities include better training and greater dedication of professional staff, the coordinated approach to patient care, greater success in preventing complications due to earlier mobilization of the patient and more attention to preventive measures, and emphasis on patient and family education and involvement in care.

## Clinical Evaluation During Acute Care

Recommendation: The evaluation of patients with acute strokes should include initial and followup assessments of medical and neurological problems, functional health patterns, complications, and social and environmental factors that may influence discharge decisions. Information in each of these areas should be fully documented in the medical record. (Research evidence = NA; expert opinion = strong consensus.)

The objectives of clinical evaluation are to verify the diagnosis of stroke; document its etiology, pathology, and neurobehavioral manifestations; and assess any comorbid conditions or abnormalities of functional health patterns that may affect clinical management. Types of information to be obtained are listed in Table 8. This information is essential in guiding treatment decisions during the acute care period. Followup examinations document responses to treatment, the evolution of neurological deficits, and any complications that may occur.

Table 8. Clinical evaluation during the acute hospitalization

General clinical assessment: history, neurological and medical examinations, and selected laboratory tests; - Functional and clinical status prior to stroke.; - Stroke etiology and location.; - Type(s), severity, and trajectories of neurological deficits.; - Type(s) and severity of comorbid diseases.; - Complications experienced during acute hospitalization.; - Functional health patterns: nutrition and hydration, ability to swallow, bowel and bladder continence, skin integrity, activity tolerance, sleep patterns.
Social and environmental factors for discharge planning; - Previous living situation and family port.; - Ethnicity/language.; - Adjustment of patient and family to illness.; - Patient and family preferences.; - Characteristics of potential postdischarge environments.
Standardized instruments (numbers in parentheses refer to attachment tables in this guideline); - Level of consciousness (1).; - Stroke deficit scale (2).; - Global disability scale (3).

The use of simple standardized instruments facilitates systematic and reliable documentation of the patient's state of consciousness, neurological impairments, and global disability on admission and at intervals during the acute care period. Even though the clinical neurological examination addresses each of these factors, they are often incompletely or inconsistently recorded. The Glasgow Coma Scale (see Attachment 1) assesses changes in levels of consciousness as manifested by eye opening, motor responses, and verbal responses to voice commands or painful stimuli. A stroke deficit scale permits systematic documentation of changes in neurological deficits in motor functions, mentation, and language (see Attachment 2). A global measure of disability such as the Rankin Scale (see Attachment 3), while relatively insensitive to change, provides a simple measure of the overall level of disability.

Discharge planning requires close involvement of the patient and family. It needs to explore social and environmental factors and preferences that will influence rehabilitation decisions, the choice of community residence, and postdischarge medical services.

## Preventing Recurrent Strokes

Recommendation: Cause-specific measures to prevent recurrent stroke should be considered and implemented in all patients. (Research evidence = A; expert opinion = strong consensus.)

Patients who have had a stroke are at substantial risk of a recurrence (7 to 10 percent, per year). The choice of therapy depends on the etiology of the stroke. Surgical treatment of cerebral aneurysms after subarachnoid hemorrhage is effective in reducing recurrences in selected cases. Carotid endarterectomy should be considered in patients with minor acute ischemic stroke or transient ischemic attack, if the ipsilateral carotid artery is 70 to 99 percent obstructed. Evidence that the procedure can reduce recurrences under these circumstances is convincing, if the patient is not at major surgical risk (European Carotid Surgery Trialists Collaborative Group [ECSTCG], 1991; Mayberg, Wilson, Yatsu, et al., 1991; North American Symptomatic Carotid Endarterectomy Trial [NASCET] Collaborators, 1991). A recent clinical advisory bulletin from the National Institute of Neurological Disorders and Stroke (1994) announced the results of a clinical trial assessing carotid endarterectomy (CE) for patients with asymptomatic internal carotid artery stenosis. The trial demonstrated that CE may reduce the 5-year risk of stroke by 55 percent in patients with more than 60 percent stenosis of the carotid artery. The effectiveness of CE in lesser degrees of carotid stenosis is not known.

Anticoagulation with warfarin has been shown to reduce future cardioembolic events and/or mortality in patients with nonvalvular atrial fibrillation in five randomized clinical trials (Boston Area Anticoagulation Trial for Atrial Fibrillation, 1990; Connolly, Laupacis, Gent, et al., 1991; Ezekowitz, Bridgers, James, et al., 1992; Peterson, Boysen, Godtfredsen, et al., 1989; Stroke Prevention in Atrial Fibrillation Investigators, 1991). To achieve an acceptable benefit-to-risk ratio, clinicians should carefully monitor coagulation based on the International Normalized Ratio (INR), aiming for a ratio between 2 and 3 (Laupacis, Albers, Dunn, et al., 1992).

Antiplatelet drugs such as aspirin and ticlopidine have been shown to reduce stroke risk in patients with TIA or minor stroke (Antiplatelet Trialists Collaboration, 1988; Triclopidine Aspirin Stroke Study Group, [Bellavance], 1993). In postmyocardial infarction patients, warfarin is effective but has reported high complication rates. Aspirin should be used first for persons with TIA or minor stroke. Patients who fail aspirin, who are aspirin intolerant, or who have had a major stroke are reasonable candidates for ticlopidine (Matchar, McCrory, Barnett, et al., 1994).

Heparin is widely used for the treatment of cardiovascular abnormalities and progressive ischemic stroke (Marsh, Adams, Biller, et al., 1989) despite lack of evidence of its benefits (Adams, Brott, Crowell, et al., 1994; Jonas, 1988).

Patient education should emphasize controlling the modifiable risk factors for stroke (see Chapter 2), such as hypertension and smoking.

## Preventing Venous Thromboembolism

Recommendation: Measures to prevent deep vein thrombosis (DVT) should be implemented soon after admission and continued until the patient is no longer at high risk due to immobility. (Research evidence = A; expert opinion = strong consensus.)

All stroke patients should be evaluated for the possible presence of DVT. Deep vein thrombosis is an important cause of pulmonary embolism, morbidity, and mortality after stroke. As many as 10 percent of deaths from stroke have been attributed to pulmonary embolism (Bounds, Wiebers, Whisnant, et al., 1981; Silver, Norris, Lewis, et al., 1984). The risk of DVT and thromboembolism is increased by the paralysis of a limb and resulting immobility (Landi, D'Angelo, Boccardi, et al., 1992; Warlow, Ogston, and Douglas, 1976), and thromboembolism has been reported to occur in as many as 47 percent of untreated patients (Clagett, Anderson, and Levine, 1992). Pooled results from randomized trials have shown a 45 percent risk reduction with prophylaxis using low-dose heparin (LDH) and a 79 percent reduction with low-molecular-weight (LMW) heparin (Brandstater, Roth, and Siebens, 1992; Clagett, Anderson, and Levine, 1992; Sandercock and Willems, 1992). The Clagett article concluded that LDH and LMW heparin are preferred treatments and that warfarin, intermittent pneumatic compression, and elastic stockings are also effective. Management of the stroke patient should include early mobilization, use of elastic stockings, and, in the absence of contraindications, prophylaxis with one of the preferred agents.

## Managing Complications

### Managing Dysphagia and Preventing Aspiration

Recommendation: The patient's ability to swallow should be assessed soon after admission and before oral intake of fluids or food is begun. Training in techniques to facilitate swallowing should be implemented as soon as possible in patients with a swallowing disorder. (Research evidence = C; expert opinion = strong consensus.)

Dysphagia (impaired swallowing) occurs frequently in stroke patients and may result in aspiration and pneumonia if not diagnosed and appropriately managed (Horner, Massey, Riski, et al., 1988; Palmer and (DeChase, 1991). Aspiration is silent in as many as 40 percent of patients who aspirate. Fortunately, spontaneous improvement is frequent.

The clinical assessment of dysphagia is discussed in Chapter 3. The goals of management are to prevent aspiration, prevent dehydration and malnutrition from inadequate oral intake, and restore the patient's ability to chew and swallow safely. Compensatory treatments involve changes in posture and positioning for swallowing, learning of new swallowing maneuvers, changes in the texture of foods (e.g., thickening liquids and using pureed or semisolid foods), decreasing bolus size, and administering food by syringe. Patients who do not regain the ability to swallow safely will require parenteral or tube feeding. If long-term tube feeding is required, a gastrostomy is usually preferable to a nasogastric tube (Emick-Herring and Wood, 1990).

Evidence supporting the effectiveness of treatment is from observational studies. A carefully performed large case series found that 89 percent of patients were able to resume oral feeding and none developed aspiration pneumonia after a compensatory feeding program (Horner, Massey, Riski, et al., 1988). Controlled trials will be needed to compare the effectiveness of different treatment regimens.

### Maintaining Skin Integrity

Recommendation: Measures to maintain skin integrity should be initiated during acute care and continued throughout rehabilitation. (Research evidence = C; expert opinion = strong consensus.)

The National Survey of Stroke found that 14.5 percent of stroke patients develop pressure sores (Roth, 1991). Patients who are comatose, severely paralyzed, obese, or incontinent of bladder or bowel, or who have muscle spasticity are at unusually high risk. Steps to maintain skin integrity include:

- Systematic daily inspection of the skin to detect areas of incipient breakdown, paying particular attention to areas over bony prominences.
- Gentle routine skin cleansing.
- Protection from exposure to moisture (e.g., urine, perspiration).
- Avoidance of skin injury due to friction or excessive pressure through use of proper positioning, turning, and transferring techniques; and by judicious use of barrier sprays, lubricants, special mattresses, and protective dressings and padding.
- Careful attention to the maintenance of adequate hydration and nutrition.
- Efforts to improve the patient's mobility.

If the patient remains incontinent despite efforts to treat the specific cause, condom drainage in men and diapering products in men and women can help minimize the contact of urine with the skin. Prior to discharge from acute care, the patient and family need to be fully instructed in the techniques of skin care and prevention of skin breakdown. For a full discussion of skin breakdown, with recommendations for prevention and treatment of Stage I pressure ulcers, refer to the AHCPR-sponsored guideline, Pressure Ulcers in Adults: Prediction and Prevention (Panel for the Prediction and Prevention of Pressure Ulcers in Adults, 1992).

### Preventing Falls

Recommendation: The patient's risk of falling should be assessed at the time of admission and updated regularly during recovery. Methods to prevent falls depend on the type(s) and severity of the patient's disabilities. (Research evidence = C; expert opinion = strong consensus.)

Falls are the most frequent cause of injury in patients hospitalized with strokes. Hip fracture is a common complication (Poplingher and Pillar, 1985). The risk of falls is increased by sensorimotor deficits that lead to problems with mobility, balance, or coordination; and by confusion, perceptual deficits, visual impairments, and problems with communication that interfere with a patient's ability to ask for assistance or make needs known. Acute illnesses, generalized weakness, and drug side effects compound risks due to neurological deficits. Patients with visual neglect and those who are slow in performing tasks are at unusually high risk of multiple accidents (Diller and Weinberg, 1970) and of running into obstacles (Webster, Rapport, Godlewski, et al., 1994). Behavioral impulsivity, older age, a history of previous falls, and multiple transfers increase the risk of falls in patients with right hemisphere strokes (Rapport, Webster, Fleming, et al., 1993).

Assessment should address the patient's risk factors and also potential hazards in the hospital environment (e.g., the surface of floors, lighting, and placement of and access to toilet facilities). The nursing staff usually has primary responsibility for assessment and for implementing preventive measures, but all clinicians should participate in fall prevention. A risk reduction program includes careful supervision of high-risk patients, toileting at regular intervals, supervised transfer and ambulation, nurse call systems suited to a patient's abilities, hospital-wide fall prevention programs, and--extremely important--adequate patient and family education.

### Managing Bladder Function

Recommendation: In cases where a catheter is inserted during the acute phase, the catheter should be removed as soon as possible. Chronic use of indwelling catheters should be limited to patients in whom incontinence or urinary retention cannot be otherwise treated. (Research evidence = C; expert opinion = strong consensus.)

Problems with bladder control and incontinence are common after stroke, but they resolve spontaneously in the large majority of patients (Brocklehurst, Andrews, Richards, et al., 1985). Causes include neurological deficits that lead to bladder hypertonicity, bladder hypotonicity with overflow incontinence, or cognitive or communication deficits with the resultant inability to recognize the need to void or to make the need known (Gelber, Good, Laven, et al., 1993). Persistent incontinence confers a poor long-term prognosis for functional recovery (Jongbloed, 1986; Reding, Winter, Hochrein, et al., 1987).

Use of an indwelling catheter should be limited to patients with incontinence due to urinary retention that cannot be otherwise treated, severely impaired patients with skin breakdown in whom frequent bed or clothing changes would be difficult or painful, and patients in whom incontinence interferes with monitoring of fluid and electrolyte balance. Chronic use of indwelling catheters increases the risk of bacteriuria and urinary tract infection (Bjork, Pelletier, and Tight, 1984; Sabanthan, Castleden, and Mitchell, 1985; Warren, Tenney, Hoopes, et al., 1982) and should be avoided (Sedrat and Hecht, 1993). Urinary retention can be safely managed with clean intermittent catheterization (Bennett and Diokno, 1984; Maynard and Diokno, 1984; Webb, Lawson, and Neal, 1990). Whether an indwelling or intermittent straight catheter is used, good catheter care is the best way to prevent urinary infection. Bacteriuria can be identified by urine cultures, but treatment with antibiotics should generally be reserved for patients with symptomatic urinary tract infections.

For further discussion of the management of urinary incontinence, see the AHCPR-sponsored guideline, Urinary Incontinence in Adults (Urinary Incontinence Guideline Panel, 1992).

### Preventing or Controlling Seizures

Recommendation: Patients who have had seizures after stroke should be given anticonvulsant medication to prevent recurrent seizures. (Research evidence = NA; expert opinion = consensus.)

Seizures are a potential complication of stroke and, if not controlled, can be potentially life threatening. Seizures can occur at the time of the acute stroke, during the first few days, or several months after the event. No study has specifically tested the usefulness of anticonvulsant medications in preventing or controlling seizures following stroke. Drugs that have been proven to be of value in preventing seizures of other causes, however, are recommended for patients who have had one or more seizures following stroke. The routine prophylactic administration of anticonvulsants to stroke survivors who have not had seizures should be avoided.

### Early Mobilization and Return to Self Care

Recommendation: The patient with an acute stroke should be mobilized as soon after admission as is medically feasible. (Research evidence = C; expert opinion = strong consensus.)

Recommendation: The patient should be encouraged to perform self-care activities as soon as medically feasible and, if necessary, should be offered compensatory training to overcome disabilities. (Research evidence = NA; expert opinion = strong consensus.)

Early mobilization helps prevent DVT, skin breakdown, contracture formation, constipation, and pneumonia. It has positive psychological effects on both the patient and the family. Direct evidence of benefit is provided by controlled studies that have shown better orthostatic tolerance and earlier improvement of ADL performance (Asberg, 1989); earlier ambulation (Hayes and Carroll, 1986); and earlier return of mental, motor, and ADL performance ) (see Table 9).Benefits in these studies were transient, however, and bias cannot be excluded since none used randomization to assign subjects to treatment or control groups.

Table 9. Evidence on the benefits of early mobilization of the stroke patient

Author, Year, Country | Purpose, Study design Duration of deficits Number of subjects | Outcome measures Maximum followup | Conclusions/Comments
Asberg (1989) Sweden | Test benefits of early activation of the patient after an acute stroke Non-RCT (two wards admitted on alternate days) Acute deficits N=63 | Orthostatic tolerance ADL (Katz) F/U until 3 months | Early activation improved orthostatic tolerance and led to transient ADL benefit. Not clear whether ADL effects were due to early activation or to increased nurse contact.
Hayes and Carroll (1986) United States | Test benefits of early rehabilitation Non-RCT Acute deficits N=30 | Ambulatory ability ADL F/U until discharge | Nonsignificant results to favor early intervention. No significant differences in outcomes.
Hamrin (1982a and 1982b) Sweden | Test early activation in daily nursing care Non-RCT Acute deficits N=112 | Activity index Mortality F/U until 3 months | No significant differences at discharge or 3 months.

Note: ADL = activities of daily living, F/U = followup, RCT = randomized controlled trial.

Indirect evidence of the benefits of early mobilization and rehabilitation therapy is suggested by the superiority of acute care stroke units in reducing mortality and improving functional outcomes. Early mobilization and early implementation of therapy are intrinsic components of care on stroke units and may have contributed to improved outcomes.

Mobilization is recommended as soon as the patient's medical and neurological condition permits and, if possible, within 24 to 48 hours of admission. Mobilization will need to be delayed or approached with caution in patients with coma, severe obtundation, progressing neurological signs or symptoms, subarachnoid or intracerebral hemorrhage, severe or persistent orthostatic hypotension, and acute myocardial infarction.

The rate and extent of mobilization depend on the patient's condition. Frequent position changes in bed and daily passive and active range of motion exercises of limbs are part of care from the time of admission. Proper positioning helps reduce the risk of aspiration, skin breakdown, joint contractures, and injury to joints in involved limbs. Important considerations include using a pullsheet to pull a patient up in bed rather than lifting under the arms, ensuring maintenance of therapeutic positions and the support of limbs in anatomically normal positions, and adequate support in bed. Range of motion exercises of joints in involved limbs reduce the risk of contracture and DVT.

Assessment of mobility begins with evaluating the patient's ability to turn from side to side and move up and sit up in bed, and then progresses to examining the ability to sit on the edge of the bed. Assistance and guarding are required when sitting is begun to protect both the patient and provider. The possibility of orthostatic hypotension needs to be carefully monitored. Mobilization progresses to patient transfers to a chair, commode, sofa, or wheelchair (and sitting on these); and finally coming to a standing position, bearing weight, and walking. Decisions on appropriate seating depend on sitting balance, endurance, and the need for pressure reduction. Safety, comfort, and maximizing mobility and independence are each important considerations. Transfer techniques should be taught by rehabilitation professionals who are expert in them. These techniques need to be used consistently by all who transfer the patient.

Self-care activities such as eating, grooming, toileting, and dressing should also be encouraged as soon as possible. Active participation in self care helps the patient resume control and increase strength, endurance, and awareness of the environment. Compensatory training can facilitate progress by teaching adaptive techniques to overcome disabilities. Mental activity is as important as physical activities, and efforts to encourage communication, problem solving, and social activity are very much part of the acute care process in suitable patients.

## Patient and Family Support and Education During the Acute Hospitalization

Recommendation: Patients who survive the acute stroke, and their families, should be thoroughly instructed in the effects and prognosis of the stroke, potential complications, and the needs and rationales for treatments. (Research evidence = NA; expert opinion = consensus.)

Stroke is a catastrophic event for the patient and family. Survivors have to confront resulting disabilities and the pervasive effects a stroke may have on their lives. Families, in turn, have to learn to provide support and adjust to altered relationships with a family member who has disabilities.

Important goals are to provide support for the patient and family during this time of need and to ensure that they gain a realistic understanding of the consequences of stroke and the objectives and methods of various treatments. Since the anxiety and stress associated with an acute stroke often interfere with the ability of the patient and family to comprehend the full meaning of the event or its treatment, understanding rather than mere explanation must be a goal of education.

## Planning for Discharge From Acute Care

Recommendation: Discharge planning should begin at the time of admission. Goals are to determine the need for rehabilitation, arrange the best possible living environment, and assure continuity of care after discharge. (Research evidence = NA; expert opinion = strong consensus.)

Effective discharge planning will contribute to better patient outcomes and at the same time help to improve the efficiency and cost effectiveness of hospital care. The family and patient need to be intimately involved in the process of exploring needs and expectations for future medical and rehabilitative services and potential living options. Patient and family preferences and the availability of support by family or involved others will be important determinants of the decisions that are made. While final arrangements will depend primarily on the patient's clinical course, early attention to these issues will greatly facilitate timely discharges.

Health professionals who are responsible for the patient's care during the acute hospitalization are also responsible for ensuring continuity of services following discharge. An important part of this responsibility is identifying patients who are candidates for a structured rehabilitation program. Decisions about referral to further rehabilitation are the subject of Chapter 5. Screening procedures should be implemented as soon as the patient's medical and neurological status permits.