# Assessment Methods for Patients With Strokes

## Introduction

Objectives of assessment are to:

- Document the diagnosis of stroke, its etiology, area of the brain involved, and clinical manifestations.
- Identify treatment needs during the acute phase.
- Identify patients who are most likely to benefit from rehabilitation.
- Select the appropriate type of rehabilitation setting.
- Provide the basis for creating a rehabilitation treatment plan.
- Monitor progress during rehabilitation and facilitate discharge planning.
- Monitor progress after return to a community residence.

To achieve these objectives, assessments must be performed by people skilled in rehabilitation, using a combination of clinical examinations and well-validated standardized measures. A battery of instruments is often required because of the varied clinical manifestations of stroke. Also, the goals of assessment change over the clinical course of stroke--from initial concern with survival, level of consciousness, and responses to acute treatments--to a later focus on specific neurological impairments and, during and after rehabilitation, on functional abilities. Measurement is affected by the complex relationships among deficits, impairments, and disabilities; e.g., a patient's inability to propel a wheelchair independently could result from any combination of the following factors: motor weakness, impaired cognition, communication problems, perceptual deficits, sensorimotor deficits, limited cardiovascular endurance, or lack of motivation. Environmental factors may also contribute to the patient's disability (e.g., there could be a defect in the wheelchair or an access impediment).

At present, assessment practices vary widely, and no single measure or group of measures has been universally accepted. Numerous measures are in use, but only a few of these have been adequately validated. Also, many clinicians have been reluctant to adopt standardized instruments. Reports that formal assessments may be more reliable than clinical impressions may help to overcome this resistance (Tinetti, 1986).

In recommending assessment instruments, this guideline attempts to balance validity and comprehensiveness of assessment with practicality. It also recognizes that there may be no single best method or instrument within each domain and, in most cases, suggests several options. Attachments 1 to 13 at the end of this guideline provide tables listing recommended assessment instruments for patients with stroke. The tables briefly describe each instrument and provide information on how the instrument is used, the time required to administer it, and its principal strengths and weaknesses.

The strengths and limitations of a wide variety of assessment instruments are carefully analyzed in Measurement in Neurological Rehabilitation (Wade, 1992). This book is an invaluable reference for those interested in improving the treatment of post-stroke patients.

## Stages of Assessment

The principal stages of assessment in stroke rehabilitation are summarized in Figure 3. Additional examinations may be dictated by the needs of particular patients.

Assessment begins with a clinical evaluation at the time of admission to the acute care hospital. Subsequent examinations during the acute hospitalization document changes in neurological and medical status and responses to treatment. Screening for post-stroke rehabilitation is performed when the patient is medically and neurologically stable. On the basis of the screening, the patient may be referred to an interdisciplinary rehabilitation program or to individual rehabilitation services in an ambulatory setting, or the decision may be not to recommend rehabilitation at that time.

Stages of assessment for post-stroke rehabilitation

A detailed assessment is performed at the time of admission to a rehabilitation program to validate the appropriateness of the referral, formulate treatment goals and a rehabilitation management plan, and provide a baseline for monitoring progress. Periodic reassessment during rehabilitation documents progress and provides the information needed to adjust treatment and eventually to plan for discharge or transfer to another type of rehabilitation setting. After discharge from rehabilitation, assessment is performed to monitor adaptation to a community residence and maintenance of functional gains made during rehabilitation.

The content of assessment at each stage is discussed at its chronologic place in the course of treatment for stroke in Chapters 4 to 7. The focus of the present chapter is on assessment methods and measures.

### Criteria for Evaluating Assessment Instruments

The essential characteristics on which clinical assessment instruments are evaluated are sensibility, validity, reliability, and sensitivity to change.

- Sensibility
- refers to the instrument's overall reasonableness, importance, and ease of use. Feinstein (1987) suggests that sensibility is the major factor determining the success or failure of a clinical measure.
- Validity
- is the ability of an instrument to measure what it is intended and presumed to measure. An instrument's criterion validity is determined by comparing its results to an agreed-on gold standard. Its predictive validity is its ability to predict future outcomes.
- Reliability
- has two dimensions. Interobserver reliability refers to the ability of two different individuals who administer the instrument to a particular patient to achieve similar results. Test-retest reliability refers to whether repeated use of the measure yields consistent results in the absence of a change in the patient.
- Sensitivity to change
- is the ability of the measure to detect clinically important changes. Instruments used to monitor the patient's progress during rehabilitation must accommodate the full range of performance levels, must have scales with sufficiently fine gradations that small changes can be detected, and must permit evaluation of specific types of impairments or disabilities rather than relying solely on summary scores.

The instruments recommended in this guideline are in wide use and have been evaluated with respect to most or all of the above criteria. They are practical and feasible to administer, and they yield meaningful results that can easily be communicated to the patient and family.

## The Neurological Examination

Neurological findings that most strongly influence rehabilitation decisions are summarized in Table 4. The reader should consult a standard text for a complete discussion of the neurological examination.

Table 4. Selected results of the neurological examination

Type of deficit | Component examination | Key findings | Effect of persistent deficit on rehabilitation
Altered level of consciousness | Repeated observation and testing of responses to external stimuli. Glasgow Coma Scale. | Drowsy, stuporous, comatose. | An altered level of consciousness is a contraindication to rehabilitation.
Cognitive deficits in higher functions, memory, ability to learn | Observation; questions to probe mental functions; standardized screening test. | Degrees and types of deficits. | A severe deficit is a contraindication to rehabilitation; a moderate deficit may impede rehabilitation and needs to be incorporated into the rehabilitation management plan.
Motor deficits | Tests of strength and tone in muscles of the upper and lower extremity and face. | Degree(s) and site(s) of weakness, incoordination, abnormal movements. | Motor deficits are the primary indications for rehabilitation. Absence of any voluntary movement is a poor prognostic sign.
Disturbances in balance and coordination | Tests of coordination, sitting, standing, walking. | Degree(s) and type(s) of deficits. | Deficits impede but do not contraindicate rehabilitation.
Somatosensory deficits | Specific tests for sensory modalities (pain, touch, etc.); complex sensory tests. | Degree(s) and type(s) of deficits. | Deficits impede but do not contraindicate rehabilitation.
Disorders of vision | Pupillary responses, ocular motility, optic fundus exam, visual fields and acuity. | Visual loss or field defect; conjugate gaze deficits. | Severe visual loss or ocular motility disturbances will impede rehabilitation.
Unilateral neglect | Observation; describe complex picture; sensory testing. | One side of body or external environment ignored; often clears spontaneously. | Neglect impedes rehabilitation but is not a contraindication.
Speech and language deficits | Observation of spontaneous speech and language use; including language comprehension, and if possible, simple reading and writing skills. | Aphasia, dysarthrias, or apraxias of speech. | Severe problems in communication will impede rehabilitation. Treatment becomes an integral part of rehabilitation.
Swallowing disorder (dysphagia) | History; test of ability to swallow liquids and solids; cinefluoroscopy with barium swallow. | Abnormal swallowing mechanism, aspiration. | Dysphagia requires careful attention to avoid aspiration and pneumonia.
Affective disorders | History; observation; depression screening test. | Symptoms of depression. | Depression may impede rehabilitation, if not treated.
Pain | Description of pain by patient; observation of restrictions in range of motion; observation of facial expressions or resistance to movement. | Location and severity of pain; precipitating causes. | Pain may require specific treatment or medication. It impedes rehabilitation.

### Level of Consciousness

Disturbances in consciousness are a strong predictor of adverse outcomes after stroke. They are more likely when brain damage is extensive, especially if the brain stem is involved or when cerebral edema or increased intracranial pressure is present. A prolonged deep coma after a stroke is rare and is more likely to complicate intracranial hemorrhage than infarction.

Evaluation of the level of consciousness involves observation of the patient's spontaneous behavior, responses to external stimuli (verbal or painful), and interactions with others. It is usually described in terms of the patient's best performance as being alert, drowsy, stuporous, or comatose. Repeated observations are needed because findings often fluctuate.

### Cognitive Disorders

Disorders in higher brain functions are common after stroke. The full picture of dementia is rare after a first event but does occur as a result of multiple strokes. A general impression of memory and the ability to acquire and retain new information can be obtained from observation of the patient's interactions with other persons and from observation of responses to questions on: orientation (name, place, day of week, etc.), current events, recent personal history, arithmetic, and simple tests of recall. Additional testing with a mental status screening test (discussed later) or a neuropsychological examination is needed to define cognitive or behavioral deficits more fully. Care must be taken to distinguish cognitive deficits from difficulties in communication.

Moderate to severe higher level cognitive deficits will markedly interfere with learning new skills during rehabilitation.

### Motor Deficits

The nature and severity of motor deficits reflect the type, location, and extent of the vascular lesion. Motor deficits can occur in isolation or may be accompanied by sensory, cognitive, or speech deficits. Weakness and paralysis are the most common manifestations, but incoordination, clumsiness, involuntary movements, or abnormal postures also occur. The face, upper extremity, and lower extremity can be involved alone or in combination. Common patterns are hemiparesis (one arm and leg) and monoparesis (most commonly the upper extremity). Patients may also demonstrate apraxias of movements in which the individual does not have demonstrable muscle weakness but is unable to sequence movement patterns. Motor limitations may be subtle in some patients.

The position of involved limbs at rest and spontaneous limb movements should be noted and the strength of muscles recorded using a scale such as: grade 0 = no movement, 1 = palpable contraction or flicker, 2 = contraction with gravity eliminated, 3 = movement against gravity, 4 = movement against resistance but weaker than other side, and 5 = normal strength. Increased (spasticity) or decreased (flaccidity) muscle tone can be identified from the degree of resistance felt to rapid passive limb movement. Slow movements (bradykinesia) or motor abnormalities such as chorea, athetosis, or hemiballismus should be recorded. Examinations for abnormal muscle stretch reflexes or pathologic reflexes are traditional, but their presence does not predict recovery from stroke. The ability to walk and to perform skilled movements (e.g., handwriting or the use of utensils) also needs to be tested; standard instruments to aid in these assessments are discussed later.

Most patients experience some spontaneous improvement in motor deficits, but the degree of recovery varies widely. Persistent motor deficits are often the primary indication for rehabilitation because of their influence on the performance of daily activities.

### Disturbances in Balance and Coordination

Motor or sensory deficits and dysfunction of the cerebellum or vestibular system can produce disturbances in balance or coordination. Incoordination in the absence of motor or sensory loss is known as ataxia. Disturbances in coordination can be examined at the bedside by performing finger-to-nose, heel-to-shin, and alternating movement tests. When possible, the patient's ability to stand and walk should be tested. If a patient can walk, additional examinations such as tandem walking or the Romberg test can provide helpful information.

### Somatosensory Deficits

Somatosensory deficits can range from the loss of simple sensory modalities to complex sensory disorders. Patients complain of numbness, tingling, or abnormal sensations (dysesthesia), or they show excessive reactions to sensory stimuli (hyperesthesia). Interactions may occur between cognitive and somatosensory disturbances. The sensory examination is difficult to perform and may be unreliable in the confused or cognitively impaired patient. The bedside examination involves testing sensory modalities such as pain, temperature, touch, proprioception (sense of position), kinesthesia (sense of movement), and pallesthesia (sense of vibration). Complex somatic sensory testing includes stereognosis and graphesthesia.

Sensory deficits usually improve after stroke, although some residual loss is common. Profound sensory loss will hamper rehabilitation of motor impairments.

### Disorders of Vision

Stroke can cause visual deficits, most commonly homonymous hemianopsia. Examination of pupillary responses and ocular motility, direct observation of the ocular fundus, and measurement of corrected visual acuity and visual fields are important. A visual-field defect in the nondominant field needs to be differentiated from visual neglect since the latter often improves spontaneously, while visual-field defects usually do not improve. Stroke can also lead to complex visual deficits or disturbances in color vision. Paralysis of conjugate gaze is an unfavorable prognostic sign for survival but usually improves spontaneously in survivors. Ocular motility disturbances due to brain stem strokes may produce symptoms such as diplopia, vertigo, oscillopsia, or visual distortions. Severe visual disturbances will increase the complexity of rehabilitation.

### Unilateral Neglect

Neglect refers to a patient's lack of awareness of a specific part of the body or external environment and occurs primarily in nondominant (usually right) hemisphere strokes. In these patients, sensory stimuli (vision, hearing, somatosensory) in the left half of the environment are ignored or evoke muted responses. Severely afflicted patients will deny problems or illness or may not even recognize their own body parts. Bedside evaluation will find that the patient is turned to the right and will often not turn toward an observer on the left. Testing will demonstrate that the patient ignores items in the left visual field when asked to describe a complex picture and ignores sensory stimuli on the left. Neglect usually improves spontaneously and relatively quickly, but it will significantly complicate rehabilitation while it persists.

### Speech and Language Deficits

Aphasia is frequent after vascular events in the language-dominant hemisphere and may cause disturbances in comprehension, speech, verbal expression, reading, and writing. Bedside evaluation includes naming of objects and observing patterns of fluency, adequacy of content, prosody of speech, use of grammatical forms, ability to repeat, and comprehension of spoken language. If possible, rudimentary writing and reading should be observed.

Neuromotor disturbances (dysarthria and apraxia of speech) need to be differentiated from aphasia. Dysarthria may be due to dysfunction of the larynx, pharynx, palate, tongue, lips, or mouth. It causes difficulty in making speech sounds clearly, abnormalities in prosody, or changes in voice quality. Observation of spontaneous speech needs to be supplemented by asking the patient to say words or phrases that test specific parts of the articulatory mechanism. In apraxia of speech, the patient is unable to program a sequence of volitional movements despite the absence of motor deficits. This results in difficulty in initiating speech, inconsistent speech patterns, and difficulty in positioning the articulatory mechanism for complex speech movements.

Apraxia of speech, dysarthria, and aphasia frequently coexist. Proper management depends on the ability to differentiate among the three conditions and determine the relative contributions of each to a patient's overall speech disorder. Language patterns and speech disturbances frequently improve during recovery from stroke.

### Pain

Severe headache, neck pain, or face pain can result from either hemorrhagic or ischemic stroke. Pain can also be associated with complications of stroke such as adhesive capsulitis; a rotator cuff tear in the shoulder; reflex sympathetic dystrophy; entrapment of the ulnar, median, or peroneal nerves; decubitus ulcer; or contractures. Neurogenic pain after stroke is a particularly serious problem. This syndrome most commonly occurs with strokes involving the thalamus. It may not appear until weeks or months after the stroke's onset. It usually involves the contralateral half of the body and may be intense and relentless. On examination, patients will be very sensitive to touch. Spontaneous recovery is rare. Pain of any cause can greatly impede a patient's ability to participate in rehabilitation and may require treatment with medications, surgical procedures, or nerve blocks.

### Diagnostic Tests

Diagnostic tests are used to supplement the patient's medical history and neurological and physical examinations in order to (1) confirm the diagnosis of stroke; (2) determine its cause (subarachnoid or intracerebral hemorrhage, embolism or thrombosis), location in the brain, and extent; (3) evaluate complications of stroke and cardiovascular and other comorbid diseases that will influence treatment or clinical outcomes; and (4) assess risk factors for recurrent stroke. Test results may have an important influence on treatment decisions during acute care and on assessment of needs for rehabilitation.

Some tests, such as CT of the brain, electrocardiogram, echocardiogram, coagulation studies, complete blood count, and blood glucose, are obtained on admission because their results may influence initial management. Other studies, such as MRI, cerebral arteriography, or cerebral spinal fluid examination, may be performed for specific indications to verify the etiology of stroke or assess changes in the patient's condition. Discussion of the indications for specific diagnostic tests is beyond the scope of this guideline.

## Assessment of Comorbid Diseases

Comorbid neurological or medical diseases may affect recovery from a stroke and limit or contraindicate specific treatments or rehabilitation. Important conditions are cardiovascular diseases (ischemic heart disease, congestive heart failure, hypertension), chronic pulmonary diseases (asthma, bronchitis, emphysema), diabetes mellitus, cancer, musculoskeletal diseases (arthritis, amputations, orthopedic problems), severe psychiatric diseases, and neurological diseases (Alzheimer's or Parkinson's disease). The evaluation of these conditions is beyond the scope of this guideline.

## Assessment of Functional Health Patterns

Assessment and continuous monitoring of basic health functions are important throughout the acute care of stroke and stroke rehabilitation. Special attention should be directed to vital signs (blood pressure, heart rate, temperature, and respiration), swallowing disorders, nutrition and hydration, bowel and bladder function, skin integrity, physical activity endurance, and sleep patterns. Goals are to prevent complications or identify them early in their development so that treatment can be given and additional disability avoided.

Swallowing disorders (dysphagia) may occur due to dysfunction of the lips, mouth, tongue, palate, pharynx, larynx, or proximal esophagus. Deficits can occur in any phase of swallowing, from the oral preparatory phase to the esophageal phase. Early assessment and treatment help to prevent aspiration and dehydration or malnutrition from inadequate oral intake. Aspiration into the airway may occur before a swallow due to disordered tongue function or a delayed or absent triggering of the swallowing mechanism; during swallowing from reduced laryngeal elevation; or after swallowing as a result of residue in the pharynx, reduced pharyngeal peristalsis, or diverticulum formation (Logemann, 1986).

Assessment includes careful pharyngeal and laryngeal nerve examinations and testing of facial muscles, tongue function, and the cough response (DiIorio and Price, 1990). Observation during eating may reveal that the patient dribbles from the mouth, pockets food on one side of the mouth, coughs or chokes when swallowing, drains food or liquid from the nose, holds food in the back of the mouth for long periods, or complains of nasal burning or tickling in the throat (Emick-Herring and Wood, 1990). The quality of the patient's voice may be affected and dysphonia (wet, hoarse voice) may be noted. Videofluoroscopy using a modified barium swallow method can be used to evaluate swallowing time, pharyngeal motility, and the mechanism of aspiration (Chen, Ott, Peele, et al., 1990; Horner and Massey, 1988; Horner, Massey, Riski, et al., 1988; Linden and Siebens, 1983; Logemann, 1986; Veis and Logemann, 1985).

Adequate nutrition and hydration can be compromised by altered consciousness, dysphagia, sensory or perceptual deficits, reduced mobility, or depression, which can cause decreased interest in eating. Poor hydration or metabolic imbalance, in turn, contributes to the development of infections, pressure sores, confusion, and poor physical endurance. Assessment includes monitoring intake, body weight, urinary and fecal outputs, caloric counts, levels of serum proteins, electrolytes, and blood counts (Axelsson, Asplund, Norberg, et al., 1988).

Disturbances of bladder or bowel function are often seen. Urinary incontinence can result from inattention, mental status changes, immobility, bladder hyperreflexia or hyporeflexia, disturbances of sphincter control, or sensory loss. Persistent incontinence should be evaluated to identify treatable medical conditions such as urinary tract infections and to determine needs for external drainage or nursing measures to maintain cleanliness and prevent skin breakdown.

Alterations in bowel function can manifest either as incontinence and diarrhea or as constipation and impaction; the latter is far more common. Assessment of constipation includes careful documentation of past and present bowel habits, dietary and fluid intake, and activity.

Skin breakdown is more likely in patients with incontinence, infections, and limited mobility (Clarke and Kadhom, 1988; Gerson, 1975; [AHCPR-sponsored] Panel for the Prediction and Prevention of Pressure Ulcers in (Adults, 1992). Abnormal movement patterns, sensory deficits, and nutritional depletion compound the risk. Daily examination of the patient's skin, especially over pressure points, is the key to assessment. Assessment tools to aid in documenting and preventing pressure ulcers include the Braden Scale (Bergstrom, Braden, Laguzza, et al., 1987; Bergstrom, Demuth, and Braden, 1987; Braden, 1989;) and the Norton Scale (Norton, McLaren, and Exton-Smith, 1962).

A patient's physical activity endurance may be insufficient for performing ADL (Mol and Baker, 1991). Potentially treatable causes, such as deconditioning as a result of immobilization and cardiovascular diseases, need to be carefully evaluated. Physical activity endurance is especially important because of its influence on the pace and intensity of rehabilitation. There is no standard approach used by rehabilitation programs to evaluate physical activity endurance. Observation of symptoms during exercise; ease of fatigability; responses of blood pressure, heart rate, and rhythm; and respiration to exercise are important dimensions. Submaximal exercise stress tests are useful in suitable patients.

Disturbances of sleep patterns are common and may persist for months after a stroke. They may lead to sluggish responses that can be confused with lack of interest, lack of motivation, or depression. Sleep patterns throughout the day and night need to be carefully observed and documented.

## Assessment of Depression and Other Affective Disorders

Depression is common after stroke. The most effective means of diagnosis is a clinical interview administered by a knowledgeable mental health professional. This interview should include questions about common symptoms, their severity, and their time course. The patient's mental status and communicative abilities should be examined simultaneously so that symptoms can be interpreted in context. Assessment may be especially difficult in patients with aphasia or severe comprehension deficits. Complex situations may require intensive investigation that takes behavioral observation of the patient, self-reports, and family reports (Gordon, 1992; Hibbard, Gordon, Stein, et al., 1993). Standardized depression scales may be useful in screening for depressive symptoms and monitoring responses to treatment, but should not be relied on as the only basis for the diagnosis of depression.

Other emotional or behavioral disturbances (e.g., anxiety, mania, outbursts of uncontrolled behavior, emotionless affect, and hostility) also occur in patients with stroke but are much less common than depression. Each depends on the clinical interview for diagnosis.

## Assessment of Neuropsychological Function

Cognitive impairments detected on neurological examination or a mental status screening test warrant a thorough clinical evaluation by a mental health professional and, in selected patients, comprehensive neuropsychological testing.

Commonly used tests are shown in Table 5. Some of these tests represent batteries of subtests that tap several areas of cognition, while others examine only a single domain. The selection of tests or test batteries for a specific patient is complex and should be made by a trained neuropsychologist. This guideline does not address selection criteria or recommend any specific tests.

Table 5. Frequently used neuropsychological tests

Intelligence tests; - Wechsler Adult Intelligence Scale (WAIS); - Peabody Picture Vocabulary Test (Revised)
Memory tests; - Wechsler Memory Scale Revised (WMS-R); - Wechsler Memory Scale (WMS); - Rey Auditory Verbal Learning
Language tests; - Boston Naming Test; - Multilingual Aphasia Exam Subtests (Token Test, Controlled Oral Word Association)
Visuospatial tests; - Rey-Osterrieth Complex Figure; - Rey-Osterrieth Delayed Recall; - Raven's Progressive Matrices
Executive "higher order" measures; - Wisconsin Card Sorting
Executive "mental control" measures; - Stroop Color-Word Test
Benton test; - Benton Visual Retention Test Benton Judgment of Line Orientation
Achievement tests; - Wide-Range Achievement Test
Neuropsychological batteries; - Halstead-Reitan Battery; - Subtests (Trails A, Trails B, Finger Tapping)
Psychomotor functioning; - Grooved Pegboard
Personality tests; - Minnesota Multiphasic; - Personality Inventory (MMPI)

## Assessment of Family Functioning and Other Contextual Factors

Contextual factors, especially family structure and functioning, are important throughout rehabilitation, but become particularly critical during discharge planning and after return to a community living environment. Contextual factors pertaining to the patient, family or other caregivers, living environment, and community are summarized in Table 6. Important contextual factors include:

- Presence of a spouse or significant other.
- Whether the patient was living with family members before the stroke.
- Family members who can supply support, and their ages and health.
- Family members within reasonable distance of the patient.
- Family history (of medical, mental health, alcohol, or drug abuse problems).
- Family ethnicity and native language.
- Physical environment of potential residences.

Table 6. Important contextual factors in the patient with a stroke

Patient characteristics; - Demographics (age, gender, race, ethnicity, language, education).; - History of mental illness.; - Personal life and work history.; - Prior activity level (low to very high).; - Prior socialization (isolated to outgoing).; - Previous coping strategies.; - Preferred leisure activities and hobbies.; - Participation in social programs during rehabilitation.; - Expectations regarding stroke outcomes and need for assistance.; - Ability to mobilize port.
Family and caregiver characteristics; - Demographics (age, gender, race, ethnicity, language, education).; - Members of household and relationship to patient.; - Current developmental stage of family (young children, empty nest, retired).; - Other family members within reasonable distance.; - Other potential caregivers.; - Family history of medical or mental illness; alcohol or substance abuse.; - Family's structure and functioning.; - Family patterns of socialization.; - Capacity to provide physical, emotional, instrumental port.; - Family's coping and adaptation patterns (previous crises and responses).; - Ability to mobilize ports.; - Attitudes toward illness, treatment, and disability.; - Cultural beliefs and norms likely to influence responses to rehabilitation.; - Family occupations, income, and financial resources.; - Health insurance.
Living environment and community characteristics; - Access to building and key facilities within living quarters.; - Safety considerations.; - Access to resources and activities in community.; - Level of stimulation in home and community.
Institutions and agencies; - Prior membership or contacts with churches, synagogues, schools, special interest groups, etc.; - Availability of potentially needed resources in the community.; - Availability of health care and rehabilitation facilities.; - Home care agencies.; - Previous workplace.

Information is obtained by interviewing the patient and family.

## Recommended Standardized Assessment Instruments

Information from standardized assessment instruments complements that from the neurological examination in assessing the level of consciousness, the overall extent of neurological impairment, motor function, balance, cognition, and speech and language. Standardized instruments also facilitate evaluation of the patient's actual performance of activities such as walking and basic or instrumental activities of daily living (ADL and IADL). These are a useful adjunct to the clinical interview in assessing depression, and they can help to apply objective measures to the elusive factors of family functioning and quality of life. Good test-retest and interobserver reliability of standardized instruments is particularly valuable in monitoring a patient's progress and in assessing performance of a rehabilitation program over time.

### Overall Measures of Stroke Deficits

The Glasgow Coma Scale (see Attachment 1) provides a systematic way to monitor changes in the level of consciousness.

Stroke deficit scales (see Attachment 2) provide a quick, reliable, and valid record of recovery from neurological deficits after a stroke. Stroke scales are based on information from the neurological examination and include measures of mentation, motor function, and language. Of available instruments, the National Institutes of Health Stroke Scale and the Canadian Neurological Scale are the best validated. Advantages of these instruments include brevity, reliability, and the fact that they can be administered by physicians, nurses, or therapists. A major limitation is that both rely on interval scales that are fairly insensitive to detecting changes. Use of a summation score can be misleading, since it combines several factors that may or may not be related.

### Global Disability Measure

A global measure of disability can be used to measure stroke severity and to document recovery of function. The Rankin Scale (see Attachment 3) is the most commonly used global scale and provides a simple broad-based estimate of the amount of dependency resulting from stroke. It measures overall independence and allows comparisons to evaluate recovery over time. A limitation is that it measures only general domains of disability and lacks details to detect change.

### Measures of Disability in Basic Activities of Daily Living

Measures of disability in basic ADL are used to determine the impact of impairments, establish therapeutic goals, and monitor progress in rehabilitation. They reflect both the impact of neurological impairments and the ability to compensate for losses. They focus on actual task accomplishment rather than on the theoretic ability to perform a task.

Most basic ADL scales measure multiple activities, including dressing, feeding, bathing, toileting, and mobility tasks. Some also include measures of cognition, communication, and social behavior. The information is obtained by observing performance. The Barthel Index and the Functional Independence Measure (FIM) (see Attachment 4) have been tested extensively in rehabilitation for reliability, validity, and sensitivity, and are by far the most commonly used measures. ADL measures have limitations because they are not sensitive to change in patients with high levels of functional disability (producing a ceiling effect); may fail to detect improvements in specific self-care activities (such as different aspects of dressing); and, by focusing on task performance, do not identify the effects of specific impairments or diseases. Also, use of summation scores can be misleading because they combine functions in different areas that are not necessarily associated.

### Mental Status Assessment

Because cognitive deficits often are missed or their severity underestimated on routine neurological examinations, use of a simple, well-validated screening test can help to probe specific spheres of mental function in patients with global deficits. The Mini-Mental Status Examination (MMSE) and the Neurobehavioral Cognition Status Examination (NCSE) (see Attachment 5) are recommended. The MMSE has been used in a wide variety of populations. It has well-demonstrated validity and reliability and is brief. However, it has the disadvantage of being heavily language dependent. Therefore, it is likely to misclassify patients with aphasia. The NCSE samples a broad range of mental functions and has well-demonstrated validity, although it has not been tested for reliability in stroke.

### Measures of Motor Function and Balance

The recommended instruments for measuring motor function (see Attachment 6) have been well characterized and are useful for capturing changes at the impairment level.

The Berg Balance Assessment (see Attachment 7) has well-demonstrated reliability, validity, and sensitivity to change in stroke patients.

### Measures of Mobility

Physical performance measures provide insights into a patient's ability to perform basic mobility functions. They may be used for screening to determine the need for treatment, for measuring responses to treatment, and for discharge planning. The Rivermead Mobility Index (see Attachment 8) is recommended because it has been tested and used in stroke patients and is simple and reliable. Timed functional movements (e.g., time to walk 10 meters or the distance that can be walked in 6 minutes) should also be considered (Brandstater, de Bruin, Gowland, et al., 1983; Butland, Pang, Gross, et al., 1982; Lipkin, Scriven, Crake, et al., 1986; Wade and Hewer, 1987a; Wolfson, Whipple, Amerman, et al., 1990). Several instruments currently employed in geriatric screening and assessment, such as Tinetti Mobility Skills, Reuben Physical Performance, and Duke Mobility Skills, are promising but have not been evaluated in stroke populations.

### Assessment of Speech and Language Function

The recommended instruments for the assessment of speech and language function (see Attachment 9) are well normed and constructed and are in wide use. These tests provide comprehensive information on speech and language disorders. They also provide a baseline against which to measure progress. Although they describe a profile of a patient's language disorder, they do not necessarily reflect measurement of functional abilities, as does the Communicative Abilities in Daily Living Test (Holland, 1980). The Functional Communication Profile (Sarno, 1969) is a rehabilitation-oriented rating scale.

### Depression Scales

The instruments in Attachment 10 can be helpful in screening for depression and in monitoring responses to therapy. The instruments included are those which have been best validated in patients with stroke. Standard instruments supplement, but do not replace, the clinical interview in the diagnosis of depression.

### Measures of Complex or Instrumental Activities in Daily Living

A return to independent living requires not only the ability to perform basic activities of daily living, but also the ability to carry out more complex activities (instrumental ADL) such as shopping, meal preparation, use of the telephone, driving a car, use of public transportation, money management, and desired leisure activities. The recommended instruments (see Attachment 11) are designed to measure performance of a wide range of activities in the person's living environment. Their use permits systematic monitoring of progress after the return home and provides useful measures of responses to continued outpatient or home rehabilitation.

The skills required by these complex activities are often taught during rehabilitation. Caution must be exercised, however, in extrapolating from performance in a highly supportive rehabilitation setting to the home. Structural features of the home environment, motivation, and the availability of support may each have important effects. Valid temporal comparisons must take account of these and other contextual factors.

### Family Assessment Device

For assessing family functioning, a useful standardized instrument is the Family Assessment Device (FAD) (see Attachment 12). The FAD has demonstrated reliability and predictive validity (Byles, Bryne, Boyle, et al., 1988) and has been used frequently with families of stroke survivors. It contains 60 items that assess family problem solving, roles, communication, affective responsiveness, affective involvement, behavior control, and general functioning. Scores can be used to identify families that may benefit from further clinical evaluation, counseling, or education. A recent review concluded that another instrument, the DSM-IIIR Global Assessment of Functioning (GAF) Scale, is also useful in assessing the social functioning of family members (Goldman, Skodol, and Lave, 1992). This assessment device is also found in the DSM-IV[TM] published in 1994 (fourth edition) by the American Psychiatric Association.

### Assessment of the Quality of Life

Quality of life includes the ability to engage in life's activities, the satisfaction derived from them, and overall perceptions of health status and well-being. The person's wishes and expectations, limitations in achieving these, and value system are all important factors.

Controversy continues over the ability to define quality of life, let alone measure it reliably. Nonetheless, the concept is sufficiently important and the state of the art of measurement sufficiently advanced to warrant inclusion of selected instruments as a complement to measures of IADL (in monitoring progress after a return to a community residence).

Many different measures of health status or quality of life have been developed, but only a few have been adequately validated. The recommended measures (see Attachment 13) assess a broad range of health dimensions and have been widely used. Both are generic and not specific to stroke patients. The Medical Outcomes Study 36-Item Short-Form Survey (SF-36) has the particular advantages of being brief and capable of being administered by telephone, administered in a face-to-face interview, or self-completed. Its major limitation in stroke patients is a floor effect which suggests that disability (ADL) measures should be added to adequately document severe disabilities. The Sickness Impact Profile (SIP) is more comprehensive and includes a broad range of items that mitigate floor or ceiling effects. Limitations are that its 136 items may take the patient 30 minutes or more to complete, and that health perception items are not included. Neither the SF-36 nor the SIP has well-documented sensitivity to detect change in stroke patients.