# Epidemiology and Natural History of Stroke

## Epidemiology of Stroke

Information on stroke incidence and prevalence, mortality, etiology, and risk factors is summarized in Table 1.

Table 1. Epidemiology of stroke

Vital statistics--United States (1989)
Incidence of stroke | 500,000
Prevalence of stroke | 2,980,000
Mortality due to stroke | 147,470
Etiology of stroke (cerebral is used here to refer to the entire brain)[a]
Ischemic stroke | Percent
Cerebral thrombosis | 47-67
Cerebral embolus | 14
Subtotal | 61-81
Hemorrhagic stroke
Intracerebral | 8-16
Subarachnoid | 4-8
Subtotal | 12-24
Other or cause uncertain | 0-25
Mortality rates (ranges from published reports)[b]
30-day mortality | 17-34
1-year mortality | 25-40
3-year mortality | 32-60
Risk factors for stroke[c]
Transient ischemic attacks (TIA), especially in the presence of 70-99 percent carotid artery stenosis | Prior stroke
Hypertension | Age
Atrial fibrillation or other source of cardiac emboli | Race
Left ventricular hypertrophy | Gender
Congestive heart failure | Family history of stroke
Cigarette smoking
Coronary artery disease
Alcohol consumption
Cocaine use
Obesity
Diabetes mellitus
High serum cholesterol

Note: The 1989 estimated incidence of stroke in the United States was 500,000; however, more recent data indicate that this estimate is closer to 550,000. For more information, see Prescott, 1994.

### Incidence and Prevalence

Stroke incidence, defined as the number of acute strokes per year, depends primarily on the age, sex, and race mix of the population, whether only first strokes or all strokes are counted, whether transient ischemic attacks (TIAs) are included as well as completed strokes, and the diagnostic criteria used.

The average age-adjusted incidence rate of first strokes has been reported to be 114 per 100,000 but ranges from 81 to 150 per 100,000 in different studies (Terent, 1993). Men have 30 to 80 percent higher rates than women (Broderick, Phillips, Whisnant, et al., 1989; Harmsen, Tsipogianni, and Wilhelmsen, 1992; Wolf, D'Agostino, O'Neal, et al., 1992). The incidence of stroke doubles with every decade after 55 years of age (Dyken, Wolf, Barnett, et al., 1984). In Rochester, Minnesota (1980 to 1984), incidence increased nearly ninefold between ages 55 to 64 and 85 years or over (Broderick, Phillips, Whisnant, et al., 1989). Stroke rates are 50 percent higher in African-American men than in white men, and 130 percent higher in African-American women than in white women (Gillum, 1988).

First-ever strokes account for about 75 percent of acute events and recurrent strokes for about 25 percent (Terent, 1993). The recurrence rate is 7 to 10 percent per year and is highest in the first year after a first stroke. In the Framingham Study, recurrence was found to be particularly common for thrombotic stroke and more frequent in men (Sacco, Wolf, Kannel, et al., 1982).

Stroke prevalence--the number of living persons at any given time who have had a stroke--depends on the interaction of incidence and survival. Studies in Rochester, Minnesota, have found stroke prevalence to be 500 to 800 cases per 100,000 population (Matsumoto, Whisnant, Kurland, et al., 1973; Whisnant, Fitzgibbons, Kurland, et al. , 1971). These figures are similar to those of other countries (Terent, 1993).

### Mortality

The average 30-day case fatality rate from stroke in the 1970s and 1980s was 21 percent, with a range from 17 percent (Broderick, Phillips, Whisnant, et al., 1989) to 34 percent (Bonita, Beaglehole, and North, 1984); 1-year mortality ranged from 25 to 40 percent; and 3-year mortality from 32 to 60 percent. Ten-year survival in the Framingham Study is 35 percent (Wolf, D'Agostino, O'Neal, et al., 1992). Hence, about half of the people with first strokes live for 3 or more years and more than one-third live for 10 years. Mortality rates for intracerebral hemorrhages are much higher than those for infarction. In Rochester (1984), the 30-day case fatality rate was 48 percent for intracerebral hemorrhage compared with 17 percent for all strokes (Broderick, Phillips, Whisnant, et al., 1989).

Stroke mortality rates have been declining steadily since the early 1950s in the United States (Broderick, Phillips, Whisnant, et al., 1989; Cooper, Sempos, Hsieh, et al., 1990) and most Western European countries (Bonita, Steward, and Beaglehole, 1990). The decline probably reflects the combined effects of better control of modifiable risk factors such as hypertension, earlier diagnosis, and better acute management of the patient (Broderick, Phillips, Whisnant, et al., 1989; Garraway, Whisnant, and Drury, 1983; McGovern, Burke, Sprafka, et al., 1992; Wolf, D'Agostino, O'Neal, et al., 1992).

### Etiology

Stroke etiologies can be classified broadly into atherothrombotic brain infarction, hemorrhage, or other. A classification scheme for brain infarction (ischemic strokes) developed in the multicenter TOAST trial in the United States has the advantages of clinical relevance and reliability (Adams, Bendixen, Kappelle, et al., 1993). This system divides infarctions into large artery atherosclerosis, cardioembolism, small vessel occlusions, or infarcts of undetermined cause. Hemorrhages may be intracerebral or subarachnoid. Accurate diagnoses are difficult to achieve based on clinical impressions alone and require information from laboratory studies including computed tomography (CT) scanning, magnetic resonance imaging (MRI), and angiography. Even with laboratory studies, however, the diagnosis represents a "best clinical guess" in a substantial number of patients. Definitions differ among studies and need to be taken into account when interpreting the results.

Keeping in mind uncertainties about diagnostic accuracy, community-based studies report that 61 to 81 percent of first strokes represent infarctions, 8 to 16 percent intracerebral hemorrhages, and 4 to 8 percent subarachnoid hemorrhages (Broderick, Phillips, Whisnant, et al., 1989; Kiyohara, Ueda, Hasuo, et al., 1989; Oxfordshire Community Stroke Project, 1983; Ward, Jamrozik, and Steward-Wynne, 1988) (see Table 1). Accurate diagnosis is important because of the relationship of etiology to mortality, recurrence rates, and choice of treatment.

### Risk Factors for Stroke

Risk factors for stroke can be divided into those that are potentially modifiable and those that are not (Dyken, Wolf, Barnett, et al., 1984). Most important among modifiable risk factors are TIAs, hypertension, diabetes mellitus, atrial fibrillation, left ventricular hypertrophy, and cigarette smoking. Prior stroke, age, sex, race, and family history are important nonmodifiable factors.

The paramount modifiable risk factor for stroke is hypertension. The relationship is with both diastolic and systolic blood pressure and is especially strong for levels above 160/95 mm Hg.

The presence of cardiac abnormalities such as atrial fibrillation, left ventricular hypertrophy, coronary heart disease, and congestive heart failure increases the risk of stroke at each blood pressure level. Acute myocardial infarction and atrial fibrillation predispose to embolism from cardiac thrombi, and nearly 15 percent of strokes in the Framingham Study have been attributed to atrial fibrillation (Wolf, Abbott, and Kannel, 1987). The risk of cerebral infarction is five times higher in individuals with electrocardiographic evidence of left ventricular hypertrophy even after other risk factors are taken into account. The relationship between blood lipids and stroke is not clear even though increased lipid levels have been related to carotid artery disease. Low serum cholesterol has been found in Hawaiian, Japanese, and other populations despite an increased incidence of cerebral hemorrhage (Yano, Reed, and MacLean, 1989).

The association of cigarette smoking with stroke holds for thrombotic strokes as well as intracerebral and subarachnoid hemorrhages. A recent meta-analysis of 32 studies found that smoking increased the risk of stroke by about 50 percent in both sexes and all age groups, and that risk was directly related to the number of cigarettes smoked per day (Shinton and Beevers, 1989).

Heavy consumption of alcohol, cocaine use, and obesity have also been linked to an increased incidence of stroke.

Among fixed risk factors, increasing age is by far the strongest. Seventy-two percent of strokes occur in people 65 years of age or over. Males have a higher risk of stroke than females in all but the oldest age groups, and African Americans have a twofold higher risk. In African Americans, about one-third of the increased risk is attributable to cardiovascular risk factors, another third to factors related to family income, and one-third is unexplained (Gillum, 1988).

## Natural History of Recovery in Stroke Survivors

### Neurological Deficits

Population-based studies provide the most reliable estimates of the relative frequency of neurological impairments following stroke. Even their results, however, need to be interpreted with knowledge of the time since stroke onset because of the importance of spontaneous neurological recovery during the early weeks after a stroke. Frequencies of deficits shortly after hospital admissions are provided by the Stroke Data Bank in the United States (Foulkes, Wolf, Price, et al., 1988; Sacco, unpublished data) and a stroke registry in Finland (Kotila, Waltimo, Niemi, et al., 1984); and frequencies of deficits 6 to 12 months (and longer) after strokes are provided by this same Finnish source and the Framingham Study (Gresham, Phillips, Wolf, et al., 1979). The Stroke Data Bank records data from admissions to four urban referral centers; the other two sources are population-based. The results are summarized in Table 2. The most striking findings are the large proportion of patients with hemiparesis and the high frequencies of other neurological deficits during the acute period, and the lower frequency of motor deficits, deficits in bladder control, dysphagia, dysarthria, and aphasia 6 to 12 months after stroke.

Table 2. Neurological deficits following stroke

Neurological deficit | Acute | | Chronic
Neurological deficit | Stroke Data Bank[a] (infractions only) | Finland[b] | Finland[b] (12 months) | Framingham[c] (6 or more months)
Neurological deficit | Percent
Right hemiparesis | 44 | NR | NR | 22
Left hemiparesis | 37 | NR | NR | 23
Bilateral hemiparesis | 7 | NR | NR | 3
Total with hemiparesis | 88 | 73 | 37 | 48
Ataxia | 20 | NR | NR | NR
Motor coordination | NR | 86 | 61 | NR
Hemianopsia | 26 | NR | NR | 13
Visual-perceptual deficits | 32 | NR | 41 | NR
Aphasia | 30 | 36 | 30 | 18
Dysarthria | 48 | 57 | 21 | 16
Sensory deficits | 53 | NR | NR | 24
Cognitive deficits (memory) | 36 | NR | (31) | NR
Depression | NR | NR | 29 | NR
Bladder control | 29 | 29 | 9 | NR
Dysphagia | 12 | 13 | 4 | NR

Note: NR = not reported.

### Comorbidities in Stroke Patients

Many patients have comorbid conditions that increase the risk of recurrent stroke and compromise the patient's ability to participate in active rehabilitation. The Framingham Study examined the frequency of comorbidities in stroke survivors and matched controls and found that the stroke survivors had significantly more hypertension (67 vs. 45 percent), hypertensive heart disease (53 vs. 31 percent), coronary heart disease (32 vs. 20 percent), obesity (22 vs. 12 percent), diabetes mellitus (22 vs. 10 percent), arthritis (22 vs. 12 percent), left ventricular hypertrophy (21 vs. 6 percent), and congestive heart failure (18 vs. 5 percent) (Gresham, Phillips, Wolf, et al., 1979).

### Time Course of Recovery From Stroke

Neurological and functional recovery occurs most rapidly in the first 1 to 3 months after a stroke (Kelly-Hayes, Wolf, Kase, et al., 1989; Skilbeck, Wade, Hewer, et al., 1983), but some patients continue to progress after that time, especially with respect to language and visuospatial functions (Andrews, Brocklehurst, Richards, et al., 1981; Hier, Mondlock, and Caplan, 1983; Meerwaldt, 1983; Skilbeck, Wade, Hewer, et al., 1983). In Rochester, Minnesota, the proportion of patients with strokes who were "moderately severely" or "severely" disabled (Rankin grades IV or V) decreased from 58 percent at the time of stroke onset to 26 percent at discharge, and 17 percent among survivors after 6 months but remained relatively constant thereafter (Dombovy, Basford, Whisnant, et al., 1987). In Framingham, improvement in motor strength and performance of self-care functions slowed 3 months after stroke, but continued at a reduced pace throughout the first year, especially in patients with cerebral infarctions (Kelly-Hayes, Wolf, Kase, et al., 1989). Cognitive function improved only during the first 3 months. The Durham County Study (Duncan, 1992) found dramatic recovery of motor function during the first 30 days and slower but continued improvement thereafter in more severely impaired individuals. Arguments that neural and functional recovery can continue beyond 3 to 6 months are supported by a recent study in which patients with motor deficits were followed for 6 months after discharge from a rehabilitation unit (Ferruci, Bandinelli, Guralnik, et al., 1993). Though time since the onset of stroke was not reported, it is reasonable to assume that most patients were at least 2 months "poststroke" at the time of discharge. Neuromuscular function, mobility, and activities of daily living continued to improve during followup, especially in more severely impaired patients.

### Disability After Stroke

#### Mobility

Mobility problems are common during the acute stroke period, but a large majority of survivors are able to walk with or without assistance 6 months to a year later. Only 27 percent of enrollees in the Frenchay Health District Stroke Registry were able to walk independently during the first week after their strokes, but 85 percent were able to do so after 6 months (Wade and Hewer, 1987a). Seventy-eight percent of long-term stroke survivors in the Framingham Study were able to walk (Gresham, Phillips, Wolf, et al., 1979).

#### Activities of Daily Living

"Basic" activities of daily living (ADL) include mobility and self-care functions such as dressing, bathing, feeding, toileting, grooming, and transfers (e.g., chair to bed, in and out of bath) that a person must be able to perform to be independent. "Instrumental" activities of daily living (IADL) are more complex functions such as use of a telephone, meal preparation, money management, use of public transportation, home and child-care tasks, and recreational and work activities. Basic ADL is usually measured on disability scales such as those recommended in Chapter 3. Findings from population-based studies (Dombovy, 1993) indicate that independence in self-care ADL improves with time. Partial or total dependence in self-care ADL was reported in 67 to 88 percent of patients within 3 weeks of onset of stroke (Dombovy, Basford, Whisnant, et al., 1987; Kojima, Omura, Wakamatsu, et al., 1990; Kotila, Waltimo, Niemi, et al., 1984; Wade and Hewer, 1987a), but in only 24 to 53 percent of survivors 6 months to 5 years after their strokes (Ahlsio, Britton, Murray, et al., 1984; Dombovy, Basford, Whisnant, et al., 1987; Gresham, Phillips, Wolf, et al., 1979; Kojima, Omura, Wakamatsu, et al., 1990; Kotila, Waltimo, Niemi, et al., 1984; Wade and Hewer, 1987a). The exclusion of fatalities needs to be considered in interpreting long-term results since these individuals usually have had more severe strokes. Frequencies and recovery patterns for different types of ADL in a community study in the United Kingdom are shown in Table 3.

Table 3. Disabilities after stroke in the Frenchay Health District, United Kingdom, during 1981-1983

Type of disability | Acute[a] | 6 months
Type of disability | Percent
Not oriented | 55 | 27
Marked communication problem | 52 | 15
Motor loss (partial or complete) | 80 | 53
Bowel incontinence | 31 | 7
Urinary incontinence | 44 | 11
Needs help with grooming | 56 | 13
Needs help with toileting | 68 | 20
Needs help with feeding | 68 | 33
Needs help with dressing | 79 | 31
Needs help with bathing | 86 | 49
Needs help with transfers from bed to chair | 70 | 19
Unable to walk independently | 73 | 15
Very severely dependent | 38 | 4
Severely dependent | 20 | 5
Moderately dependent | 15 | 12
Mildly dependent | 12 | 32
Physically independent | 12 | 47

[a] Acute figures are minimal estimates for acute stroke, since many patients were not assessed during the first week after onset.

Source: Adapted with permission from Wade, 1994.

#### Communication.

The ability to communicate is important both for successful participation in rehabilitation and for resumption of an independent life. Patients with communication deficits usually experience some degree of spontaneous improvement. One study, for example, found that the frequency of aphasia decreased from 24 percent within 7 days after stroke (with another 28 percent unassessable) to 12 percent 6 months later (Wade, Hewer, David, et al., 1986). Formal assessment may underestimate the true frequency of communication deficits, however, since 44 percent of patients and 57 percent of caregivers in this study thought speech was abnormal at the time of followup.

#### Neuropsychological Functioning

Neuropsychological disabilities can be divided broadly into cognitive dysfunction, visuospatial deficits, and affective disorders (predominantly depression). Depression is particularly common after stroke. In Finland, Kotila found depression in 44 percent of patients and other abnormal emotional reactions in 30 percent of patients 3 months after stroke, and corresponding figures of 29 and 32 percent 12 months after stroke (Kotila, Waltimo, Niemi, et al., 1984).

### Quality of Life After Stroke

Most stroke survivors experience a decrease in levels of activity and overall quality of life. In the Framingham Study, they were found to socialize less, have fewer interests and hobbies, be less able to use public transportation or perform household tasks, and be less likely to engage in vocational pursuits than a stroke-free control group (Gresham, Phillips, Wolf, et al., 1979). In another study, they consistently reported that their quality of life was worse than before the stroke and had not improved over the 2 intervening years (Ahlsio, Britton, Murray, et al., 1984). In this study, deterioration was at least as strongly related to psychological problems such as depression and anxiety as to physical dependency measured by ADL. Depression, dependence on others, and inability to return to work all contribute to diminished quality of life (Niemi, Laaksonen, Kotila, et al., 1988; Viitanen, Fugl-Meyer, Bernspang, et al., 1988).

The ability to return home is also an important dimension of the quality of life, though the resulting burden on caregivers may offset the benefits. Rates of institutionalization after stroke range from 10 to 29 percent (Dombovy, Basford, Whisnant, et al., 1987; Gresham, Phillips, Wolf, et al., 1979; Kelly-Hayes, Wolf, Kannel, et al., 1988; Kotila, Waltimo, Niemi, et al., 1984; Lehmann, DeLateur, Fowler, et al., 1975; Silliman, Wagner, and Fletcher, 1987).

### Gender Differences

Age-adjusted disability levels after stroke are similar in men and women (Wade, Hewer, David, et al., 1986). However, women report more disability and unmet social needs (Branch and Jette, 1981; Jette and Branch, 1981). Greater differences have been found in women between actual lifestyles and observed capacity to function (Kelly-Hayes, Jette, Wolf, et al., 1992). In Framingham, women are institutionalized twice as often as men (Kelly-Hayes, Wolf, Kannel, et al., 1988). Marital status is a more important predictor of the patient's ability to live independently in men than in women, due at least partly to the greater support provided by female caregivers (DeJong and Branch, 1982).

## Prediction of Functional Recovery After Stroke

A special report from the World Health Organization (1989) succinctly states the problem of predicting which patients will benefit from rehabilitation:

Since rehabilitation can be costly, the development of improved criteria for selecting patients for intensive rehabilitation is of the utmost importance. Such selection should be based on the prognosis of the recovery of function(s) in three main groups: (1) patients who spontaneously make good recovery without rehabilitation; (2) patients who can make satisfactory recovery only through intensive rehabilitation; and (3) patients with poor recovery of function irrespective of the type of rehabilitation. (p. 1429).

Available evidence does not permit a clear delineation among these three groups of patients. Controlled clinical trials are needed to identify who is most likely to benefit from rehabilitation. Until these studies are performed, clinicians must rely on observational studies to estimate the effects of different patient characteristics on functional recovery. These studies do not, however, differentiate the benefits of rehabilitation from spontaneous recovery.

In more than a single study, patient characteristics that have been associated with poorer functional outcomes include severe initial functional deficits, severe initial motor deficits, persistent urinary incontinence, severe visuospatial deficits, sitting imbalance, severe aphasia, altered level of consciousness, severe cognitive deficits, major depression, severe comorbidities, disability prior to stroke, and older age. Despite their limitations, these results provide a useful starting point for identifying subgroups of stroke survivors who are likely to fall in Category 3 as defined by WHO, and in whom the potential benefits of stroke rehabilitation need to be carefully evaluated.