# Overview

## Goals of the Guideline

The primary goal of this guideline is to improve the effectiveness of rehabilitation in helping the person with disabilities from a stroke to achieve the best possible functional outcome and quality of life. The central focus is on the patient with a first stroke (of any etiology) who has developed hemiparesis with or without other neurological impairments and is a candidate for treatment in an interdisciplinary rehabilitation program. Most recommendations also apply to people with other neurological impairments from stroke, those with recurrent strokes, and those who may need limited rehabilitation services but not a comprehensive program. The emphasis is on what is best for the patient and the patient's family. Provider and reimbursement issues, while important, are not addressed in detail. Specific goals are to:

- Make available to rehabilitation professionals and primary care providers the best current knowledge and expert consensus regarding effective rehabilitation practices.
- Improve the public's and medical community's understanding of stroke rehabilitation services and their strengths and limitations.
- Improve access to rehabilitation services by increasing the awareness of patients, families, health professionals, and the public at large of the availability and capabilities of these services.
- Emphasize the patient- and family-centered nature of rehabilitation and the importance of capitalizing on patient, family, and community strengths and potentials during the rehabilitation process.
- Enhance community integration of the stroke survivor with disabilities.
- Encourage rehabilitation professionals to reexamine their practice patterns, and to target services at patients who are most likely to benefit.
- Stimulate future research to fill critical gaps in our knowledge regarding the effectiveness of stroke rehabilitation.

## What Is Stroke Rehabilitation?

An established and universally accepted definition for stroke is "acute neurologic dysfunction of vascular origin . . . with symptoms and signs corresponding to the involvement of focal areas of the brain" (World Health Organization, 1989). It can also be described as the rapid onset of neurological deficits that persist for at least 24 hours and are caused either by intracerebral or subarachnoid hemorrhage or by partial or complete blockage of a blood vessel supplying or draining a part of the brain, leading to the infarction of brain tissue. A stroke is distinguished from a transient ischemic attack (TIA) by the fact that neurological deficits in TIAs clear spontaneously within 24 hours.

Stroke rehabilitation is a restorative learning process which seeks to hasten and maximize recovery from stroke by treating the disabilities caused by the stroke, and to prepare the stroke survivor to reintegrate as fully as possible into community life. Approaches to rehabilitation include:

- Prevention of secondary complications.
- Remediation, or treatment to reduce neurological deficits.
- Compensation to offset and adapt to residual disabilities.
- Maintenance of function over the long term.

Operationally, rehabilitation encompasses a broad array of biomedical, social, educational, and vocational interventions that can be provided in a variety of institutional and community settings. Rehabilitation professionals include physiatrists, neurologists with special interests in rehabilitation, internists, family physicians, geriatricians, rehabilitation nurses, physician assistants, physical therapists, occupational therapists, speech-language pathologists, psychologists, psychiatrists, social workers, vocational rehabilitation specialists, recreational therapists, orthotists, and dietitians. Services are often provided by an interdisciplinary team in which the specific participants will depend on the patient's physical, cognitive, and emotional disabilities and the availability of rehabilitation resources in the community.

## Need for a Guideline

The need for a stroke rehabilitation guideline stems from the magnitude of the human and economic burdens that result from stroke; wide variations in practice patterns among different communities and treatment settings; and continued controversy over the benefits of stroke rehabilitation.

Stroke is the third leading cause of death in the United States and is the leading cause of long-term disability among adults. Approximately 550,000 people suffer a stroke each year, nearly 150,000 people die from stroke, and about 3 million stroke survivors have varying degrees of residual neurological impairment (American Heart Association, 1991; Prescott, 1994). Stroke incidence doubles with each successive decade over 55 years of age (Dyken, Wolf, Barnett, et al., 1984). Incidence is about 30 percent higher in men than in women (Wolf, Cobb, and D'Agostino, 1992), about 50 percent higher in African-American men than in white men, and 2.3 times higher in African-American women than in white women (Gillum, 1988). The economic burden from stroke has been estimated to be $30 billion in health care costs and lost productivity each year (Matchar, McCrory, Barnett, et al., 1994).

Rehabilitation practice patterns in the United States vary greatly from one geographic area to another, reflecting an uneven distribution of rehabilitation facilities and professionals, differing thresholds for admission to inpatient facilities, and differences in treatment regimens. An analysis of Medicare claims for rehabilitation services received in 1991, commissioned by the Agency for Health Care Policy and Research as part of this guideline development process, found that 17 percent of patients who survived their strokes were admitted to a hospital-based inpatient rehabilitation program, 23 percent were treated in a nursing facility, and 40 percent received outpatient or home care rehabilitation services. A total of 73 percent received services in one or more of these types of settings.

These wide practice variations occurred in the face of limited evidence supporting the effectiveness of stroke rehabilitation. Though observational studies provide a wealth of information on the natural history and epidemiology of stroke, few well-controlled clinical studies document benefits from rehabilitation. Most clinical studies have focused on short-term changes in impairment or function during inpatient rehabilitation. Results have been inconsistent, and where they favor the experimental group, the difference is generally small. A particularly difficult problem has been that of distinguishing rehabilitation effects from spontaneous neurological recovery after a stroke. The most convincing evidence that rehabilitation may be effective is provided by studies that have examined the effects of treatment in stroke patients with chronic neurological impairments, thereby excluding effects of spontaneous recovery, which largely occurs during the first 6 months following a stroke.

Technical deficiencies that compromise the validity of many studies include suboptimal study designs, small sample sizes, highly selected study populations, failure to control for length of time since stroke onset, incompletely described interventions, unstandardized measures of outcome, and inadequate statistical methodologies (Dombovy, Sandok, and Basford, 1986; Ernst, 1990; Stineman and Granger, 1991).

The scarcity of scientific evidence supporting the benefits of rehabilitation has mixed implications for the guideline. On the one hand, it detracts from the strength of scientific support for recommendations and necessitates heavy reliance on professional judgment and expert opinion. On the other hand, the scarcity of evidence creates the opportunity to assess current knowledge, to develop guidelines that will help to move stroke rehabilitation toward consistent norms, and to stimulate the research that is needed to put individual interventions and comprehensive rehabilitation programs on firm scientific ground. This guideline is a first step and will need to be updated as new information becomes available.

## Priorities for Future Research

Research is urgently needed to address critical questions about the effectiveness and cost effectiveness of stroke rehabilitation. Highest priority should be given to well-controlled experimental studies that assess functional performance and quality-of-life outcomes and the cost effectiveness of alternative service delivery strategies. Goals should be to:

- Identify the characteristics of patients who are most likely to benefit from rehabilitation.
- Determine the optimal program for rehabilitation for different types of patients.
- Identify factors that determine the optimal timing, intensity, and duration of rehabilitation.
- Determine the effectiveness of specific treatments or combinations of treatments in reducing impairments or improving function.
- Develop and validate standardized tests for use in monitoring post-stroke rehabilitation.

In most instances, preference should be given to single- or multiple-center randomized clinical trials because of their greater scientific validity. Ethical concerns about withholding treatment from stroke survivors can be overcome by using "usual care" rather than "no treatment" controls. Cohort and case-control studies can also yield valuable information if they are well designed and properly analyzed. Population-based studies that collect data prospectively on representative samples of patients with completed strokes are especially useful.

## Framework for the Guideline

### Conceptual Model

The goals of rehabilitation can be visualized according to the conceptual framework of disablement developed in the World Health Organization's (WHO) International Classification of Impairments, Disabilities, and Handicaps (ICIDH) (World Health Organization, 1980) and Nagi's functional limitation" model (Nagi, 1965). The former classifies disablement in terms of "disease," "impairment," "disability," and "handicap," in which disease is the underlying diagnosis and pathologic process, impairment is the loss or abnormality of physical or psychological capacities, disability is a restriction or lack of ability of a person to perform an activity in daily life, and handicap is a disadvantage resulting from an impairment or disability that limits or prevents fulfillment of a role that is normal for that person.

Nagi, on the other hand, emphasizes "pathology," "impairment," "functional limitation," and "disability," where pathology is the "interruption or interference of normal bodily processes or structures"; impairment is "loss or abnormality of mental, emotional, physiological, or anatomical structure or function"; functional limitation is "restriction or lack of ability to perform an action or activity in the manner or within the range considered normal"; and disability is the "inability or limitation in performing socially defined activities and roles expected of individuals within a social or physical environment." The disability model envisioned by Nagi has the advantages of emphasizing the causative role of risk factors and the importance of the quality of life. "Disability" in Nagi's framework is equivalent to "handicap" in WHO's framework and avoids the negative implications attached to this term.

Figure 1 combines concepts from the Nagi and WHO models and relates them across three levels of concern: the organ level, person level, and societal level. At the organ level, pathology determines impairments. These contribute to disability or difficulty performing tasks at the person level. Disability, a central concept in this model, is also strongly influenced by contextual factors such as physical barriers, social and cultural factors, and the attitudes of those involved. Disability, in combination with societal expectations, contributes to handicap or social disadvantage at the societal level. The lower portion of Figure 1 shows how functional assessment and interventions differ for the three levels. Functional assessment determines unmet needs which then become the focus of medical or restorative, adaptive, environmental, or social interventions. This guideline adheres to the nomenclature shown in Figure 1, which is widely accepted by rehabilitation professionals.

Relationship of functional assessment and interventions to the World Health Organization's impairment, disability, and handicap model

### Outcome Measures

Potential measures of the success of stroke rehabilitation include:

- Survival.
- Normalized health patterns (such as nutrition, continence, and sleep).
- Freedom from physical pain and emotional distress.
- Cognitive and communicative abilities.
- Freedom from impairments affecting motor control, mobility of joints, sensation, speech and language, and other areas.
- Independence in mobility and the basic activities of daily living.
- Independence in complex daily functions and social roles.
- Successful family function and adaptation.
- Quality of life.

Actual performance of a function is a better measure of success than the capacity to perform the function in the supportive environment of a rehabilitation program. Motivation, confidence, stimulation, and environmental factors can all strongly affect actual performance.

The ability of a person with a stroke to return home after treatment is usually regarded as a desirable outcome. This may not be the case, however, if the person's needs for physical care and support impose intolerable burdens on caregivers.

### Scope of the Guideline

This guideline is intended for use by all of the professionals who participate in post-stroke rehabilitation. It is specifically directed at the patient with a first stroke who has residual hemiparesis with or without other neurological impairments. Most recommendations will also apply to the person with a recurrent stroke or with stroke-related neurological impairments in the absence of hemiparesis.

The guideline addresses the rehabilitation needs of the person who has had a stroke from the acute hospital stay through subsequent rehabilitation and return to the community. Its scope corresponds to the clinical flow diagram for stroke rehabilitation shown in Figure 2. Most patients with strokes are initially admitted to a stroke unit or general medical service of an acute care hospital. The primary objectives of rehabilitation services are to prevent complications and to mobilize the patient, mentally as well as physically, as soon as medically feasible. Screening for rehabilitation is performed when the patient's condition has stabilized--often within 3 to 5 days if the clinical course is uncomplicated. Patients who recover completely will not need rehabilitation. Those who remain severely incapacitated are not likely to benefit at that time; however, they may improve sufficiently over a further period of recuperation and should be reevaluated at a later date.

Clinical flow diagram for stroke rehabilitation

Between these extremes are patients with persistent functional deficits who are potential candidates for individual rehabilitation services or an interdisciplinary program. The choice of rehabilitation setting will depend on careful evaluation of clinical findings and the capabilities of rehabilitation facilities in a given community. The fundamental components of any program are baseline assessment, development of rehabilitation goals and a plan for achieving them, implementation of interventions, and monitoring of progress.

When goals have been achieved or a plateau in progress has been reached, the patient is discharged from rehabilitation or transferred to another type of setting (e.g., to an outpatient or home program from an inpatient setting). Transition to a community residence or the cessation of rehabilitation services often raises difficult issues of adaptation and continuity of care that need to be addressed.

### Nomenclature in Stroke Rehabilitation

This guideline employs a standard terminology to describe rehabilitation settings, programs, interventions, and participants. Following are definitions of some of the more important terms used. See the Glossary for other definitions.

#### Rehabilitation Settings

The terms used to describe various rehabilitation settings are:

- Acute care hospital.
- A full-service hospital where patients with an acute stroke are treated either in a medical service or in a specialized stroke unit, and where rehabilitation interventions are normally begun during the acute phase.
- Inpatient rehabilitation
- . Rehabilitation performed during an inpatient stay in a freestanding rehabilitation hospital or a rehabilitation unit of an acute care hospital. The term inpatient is also used to refer generically to programs where the patient is in residence during treatment, whether in an acute care hospital, a rehabilitation hospital, or a nursing facility.
- Nursing facility rehabilitation
- . Rehabilitation performed during a stay in a nursing facility. Nursing facilities vary widely in their rehabilitation capabilities, ranging from maintenance care to comprehensive and intense rehabilitation programs.
- Outpatient rehabilitation
- . Rehabilitation performed in an outpatient facility that is either freestanding or attached to an acute care or rehabilitation hospital. Day hospital care is a subset of outpatient rehabilitation in which the patient spends a major part of the day in an outpatient rehabilitation facility.
- Home-based rehabilitation.
- A rehabilitation program provided in the patient's place of residence.

#### The Spectrum of Rehabilitation Care

Rehabilitation ranges from individual services by a single clinician or discipline for patients with circumscribed deficits to comprehensive rehabilitation programs that encompass multiple, interactive services provided by an interdisciplinary team. In between are programs of varying complexity which involve two or more rehabilitation disciplines, coordinated in some fashion.

Rehabilitation programs can also be described in terms of their intensity, measured as the number and duration of services per day or per week. In this guideline, an intense program involves two or more rehabilitation disciplines, 5 days a week, with a minimum of 3 hours of active rehabilitation each day. Less intense programs cover a wide range, from 1 hour of services two or three times a week upward.

Some sources use the term acute rehabilitation to denote inpatient hospital rehabilitation and subacute rehabilitation to denote a program conducted in a nursing facility. Instead, this guideline substitutes categories of intensity to describe the actual content of programs wherever they take place. The trend toward providing intense rehabilitation programs in nursing facilities and at home, as well as in hospitals, supports this approach.^ 1 ^

1 The Commission on Accreditation of Rehabilitation Facilities (CARF) has proposed a new classification of accredited hospital and nursing facility programs into one "acute" and two "subacute" categories based on the intensity of rehabilitation provided and the medical and nursing needs of patients. The Joint Commission on Accreditation of Healthcare Organizations (JCAHO) is also considering distinguishing between "acute" and "subacute" levels of care.

#### The Recipient of Rehabilitation Services

The guideline uses the term patient to refer to a recipient of a rehabilitation program or services regardless of setting. (In some sources, a distinction is made among settings, with a patient receiving services in an inpatient hospital rehabilitation program, a resident in a nursing facility, and a client in a home-based or outpatient program.) The term stroke survivor is often used in the guideline when referring to a person who has had a stroke but is not necessarily a patient at present (e.g., the person may have completed treatment and reentered the community) or when the focus of the discussion is on the person as an individual rather than as a patient. The terms person and individual are also used.

#### The Family and Caregivers

The term family is used broadly to include both relatives and friends with whom the patient was living before the stroke or who are close to the patient and involved in the patient's treatment. The term caregiver refers to the one or two individuals who provide most of the day-to-day support needed by the stroke survivor at home.

## Methodology

### Panel Selection and Guideline Development

#### Panel Selection

The guideline was developed by a panel of experts and consultants representing the medical and rehabilitation specialties involved in stroke rehabilitation. Medical specialties included family practice, geriatrics, internal medicine, neurology, physiatry, and psychiatry. Other rehabilitation specialties included occupational therapy, physical therapy, psychology, rehabilitation nursing, social work, speech-language pathology, and recreational therapy. Consumer representatives also helped with the development of the guideline. Each panelist was nominated by the relevant professional society and was approved by the Agency for Health Care Policy and Research.

#### Guideline Formulation

The steps in formulating the guideline were as follows:

- Establishment of the scope of the guideline, including clinical issues to be addressed, patient population to be emphasized, target audience, and the measures of patient benefits and harms by which the rehabilitation process or individual interventions should be evaluated.
- An extensive search of the scientific literature and literature on rehabilitation procedures, costs, practice variations, and other policy issues. Sources included MEDLINE, several social science data bases, published dissertations, and additional citations identified from the bibliographies of review articles and from recommendations by panel members or consultants. More than 1,900 articles were reviewed and are listed in the Guideline Technical Report, and nearly 500 are cited in this Clinical Practice Guideline. (See later description of these documents.) The primary emphasis has been on experimental studies, but review articles and observational studies have been included if they provided information critical to understanding the natural history of stroke or the effects of rehabilitation. Animal studies and manuscripts written in other than the English language were excluded.
- Analysis of Medicare claims for a nationwide 10-percent sample of beneficiaries with admission for stroke to an acute care hospital in 1991. This analysis obtained data on the utilization and costs of rehabilitation services received during the first 6 months following stroke and documented practice variations by geographic area.
- Extensive discussion of the evidence by the panel and related formulation of recommendations. Each recommendation was supported by at least 75 percent of panel members.
- Development of four documents: A comprehensive Guideline Technical Report, this Clinical Practice Guideline emphasizing guidance for practitioners, a Quick Reference Guide for Clinicians, and a Patient and Family Guide. The Guideline Technical Report includes an analysis of policy issues and recommendations for a research agenda in stroke rehabilitation.

#### External Review

Four stages of external review took place:

- An open forum in Washington, DC, which provided an opportunity for professional and provider organizations, manufacturers, pharmaceutical firms, and individuals to present either written or oral statements. The 34 statements received provided valuable perspectives.
- Detailed review of the full Guideline Technical Report by 44 experts in disciplines involved in stroke rehabilitation. Reviewers were asked to identify errors of omission and interpretation and to review draft recommendations, reformulate them if appropriate, and justify the changes in terms of the scientific literature or professional experience. This review was extraordinarily helpful and resulted in significant changes in the guideline and its recommendations.
- Review of the Clinical Practice Guideline, the Quick Reference Guide for Clinicians, and the Patient and Family Guide by a broad array of professional, provider, insurer, and consumer organizations in order to obtain reactions to the guidelines, assess their potential effects on the practice and costs of stroke rehabilitation, and determine their sensitivity to patient, family, and clinician concerns. The review was especially important in obtaining the views of organizations that will be participants in guideline implementation.
- Pilot testing of the Clinical Practice Guideline, the Quick Reference Guide for Clinicians, and the Patient and Family Guide by 10 provider organizations that deliver rehabilitation services and one independent case-management consultant. Each respondent was asked to estimate the overall effects of the guideline on admission policies, procedures, and quality improvement activities and to test the guideline on patients who had received or were receiving rehabilitation services and record specific ways in which the guideline differed from current practice.

### Format and Classification of Recommendations

Each guideline recommendation is justified in terms of the level of research evidence supporting it and the degree of consensus on it among panel members. The distinction between support derived from scientific studies and that derived from expert opinion is important. Well-performed and relevant scientific studies provide a higher standard of evidence when they are available, but many aspects of stroke rehabilitation have not been addressed by such studies. Expert judgments supplement research evidence by factoring in clinical experience and human values that are not easily captured in scientific studies, and by extrapolating from scientific findings that were obtained with specific populations under specific conditions to a broad clinical context.

Support for recommendations is characterized as follows

- Research Evidence:
- A.
- Supported by the results of two or more randomized controlled trials (RCTs) that have good internal validity, and also specifically address the question of interest in a group of patients comparable to the one to which the recommendation applies (external validity).
- B.
- Supported by a single RCT meeting the criteria given above for "A"-level evidence, by RCTs that only indirectly address the questions of interest, or by two or more nonrandomized clinical trials (case control or cohort studies) in which the experimental and control groups are demonstrably similar or multivariate analyses have effectively controlled for group differences.
- C.
- Supported by a single non-RCT meeting the criteria given above for "B"-level evidence, by studies using historical controls, or by studies using quasi-experimental designs such as pre- and post-treatment comparisons.
- NA (not available).
- Recommendation is not addressed by experimental studies.
- Expert Opinion:
- Strong consensus.
- Agreement among 90 percent or more of panel members and expert reviewers.
- Consensus.
- Agreement among 75 to 89 percent of panel members and expert reviewers.

## Organization of the Guideline

Chapter 2 briefly describes the epidemiology and natural history of stroke, and Chapter 3 describes methods of assessment applicable to patients with strokes. Practice recommendations are presented in the next four chapters: Chapter 4 concerns rehabilitation during the acute phase of stroke treatment; Chapter 5, the screening for further rehabilitation and choice of a rehabilitation setting; Chapter 6, management of the rehabilitation process; and Chapter 7, discharge and the return to the community. The attachments provide information on the validity, reliability, and sensitivity of panel-preferred assessment instruments used with stroke patients.