# Attachments

## Attachment A. Sample Pressure Ulcer Assessment Guide

[image]

## Attachment B. Sample Nutritional Assessment Guide for Patients With Pressure Ulcers

[image]

Attachment C. Oral and Cutaneous Signs of Vitamin or Mineral Deficiencies

Clinical Signs (by Site) | Deficiency(ies)
Oral Cavity
Cheilosis and angular stomatitis | Vitamin B2
Glossitis (i.e., pink or magenta discoloration with loss of villi) | Multiple B vitamins
Eyes
Scleral changes | Vitamin A
Bitot's spots | Vitamin A
Face
Seborrhea-like dryness and redness of nasolabial fold and eyebrows | Zinc
Upper Extremities
Purplish blotches on lightly traumatized areas (due to capillary fragility and subepithelial hemorrhages) | Vitamin C
Extreme transparency of skin of hands ("cellophane skin") | Vitamin C
Abdomen/Buttocks
Waxy, perifollicular hyperkeratosis | Vitamin A
Lower Extremities
Superficial flaking of epidermis, large flakes of dandruff | Essential fatty acids
Cracks in skin between islands of hyperkeratosis:
Pigmented | Nicotinamide (niacinamide)
Nonpigmented | Vitamin A

Note: These manifestations may be seen in disease processes other than vitamin deficiencies. If the cause is in fact a deficiency, clinical improvement should be evident 4 weeks after supplementation is begun.

Attachment D. Practical Management of Loose Bowel Movements related to Tube Feeding

Possible Cause(s) | Treatment
Antibiotic use | Lactobacilli per feeding tube (2 packets tid X 3 doses)
Lactose intolerance | Use lactose-free liquid diet
Choleretic diarrhea | Questran**, 1 g q6--8h and/or Titralac tabs, 2 q6--8h
Mild enterotoxogenic pathogens | Pepto-Bismol**, 30 mL q6--8h
Severe enterotoxogenic pathogens with WBCs in stool on Gram stain | Selected antibiotic per stool culture and sensitivity testing
Insufficient fiber | Fiber supplement, 3 g q6--8h
Idiopathic | Lomotil**, Imodium**, paregoric (Warning: This may cause reactive constipation!)

** Registered Trademark

Note: Any or all treatments may be indicated. tid = three times daily q = every WBC = White Blood Cells