# Glossary

Abscess. : A circumscribed collection of pus that forms in tissue as a result of acute or chronic localized infection. It is associated with tissue destruction and frequently swelling.

Adherent Materials. : Matter attached to the wound bed such as eschar, dirt particles, or bacteria.

Advancing Cellulitis. : See Cellulitis.

Air-Flotation Bed. : See under Support Surfaces.

Air-Fluidized Bed. : See under Support Surfaces.

Alginate Dressing. : See under Dressing.

Allergic Sensitization. : The development of antibodies to a foreign substance (e.g., medication) that results in an allergic reaction.

Alternating-Air Mattress or Overlay. : See under Support Surfaces.

Amyloidosis. : A condition characterized by the formation and accumulation of insoluble proteins (amyloid) in various organs of the body, compromising vital function. Amyloid may collect in a chronic wound, such as a pressure ulcer.

Analgesia. : Relief of pain without loss of consciousness.

Angular Stomatitis. : Single or multiple fissures at the corners of the mouth, one cause of which may be riboflavin deficiency.

Antiseptic (Topical). : Product with antimicrobial activity designed for use on skin or other superficial tissues; may damage cells.

Autolytic Debridement. : See under Debridement.

Bacteremia. : The presence of viable bacteria in the circulating blood.

Bacterial Culture. : See Culture (Bacterial).

Bitot's Spots. : Superficial, triangular, foamy grey spots on the conjunctiva that consist of keratinized epithelium and are associated with vitamin A deficiency.

Blanchable Erythema. : See under Erythema.

Body Substance Isolation (BSI). : A system of infection-control procedures routinely used with all patients to prevent cross-contamination of pathogens. The system emphasizes the use of barrier precautions to isolate potentially infectious body substances. According to Lynch, Jackson, Cummings, et al. (1987), BSI has six components. Wear gloves for anticipated contact with blood, secretions, mucous membranes, nonintact skin, and moist body substances for all patients. Change gloves before treating another patient. Handwashing between patients is essential. After other types of patient contact, wash the hands for 10 seconds with soap and friction to remove transient microbial flora, and then rinse with running water (Garner and Favero, 1986).Wear additional barriers such as gowns, plastic aprons, masks, or goggles when moist body substances (secretions, blood, or body fluids) are likely to soil the clothing or the skin or splash in the face. The panel notes that protective eyewear, mask (or a faceshield that covers the eyes and face), gloves, and in some cases protective gowns should be used for pressure ulcer irrigation when there is a reasonable expectation that wound secretions might be aerosolized. Place soiled reusable articles and linen, as well as trash, in containers that are securely sealed to prevent leaking. Double bagging is not necessary unless the outside of the bag is visibly soiled. Place needles (without recapping them) and sharp instruments in puncture-resistant, rigid containers. If such containers are not available, recapping using the one-hand technique is acceptable. Assign to private rooms those patients with diseases that could be transmitted by the airborne route (e.g., pulmonary tuberculosis) and other diseases listed under precautions for strict isolation in the category-specific isolation (CDC, 1970). The use of private rooms is also indicated for those patients likely to soil articles in their environment with body substances.

Bottoming Out. : Expression used to describe inadequate support from a mattress overlay or seat cushion as determined by a "hand check." To perform a hand check, the caregiver places an outstretched hand (palm up) under the overlay or cushion below the pressure ulcer or that part of the body at risk for a pressure ulcer. If the caregiver feels less than an inch of support material, the patient has bottomed out and the support surface is therefore inadequate.

BSI. : See Body Substance Isolation.

Caregiver. : Any individual who provides care including professional health care providers, paraprofessional care providers, and family caregivers.

Cellulitis. : Inflammation of cellular or connective tissue. Inflammation may be diminished or absent in immunosuppressed individuals.

Cellulitis (Advancing). : Cellulitis that is visibly spreading in the area of the wound. Advancement can be monitored by marking the outer edge of the cellulitis and assessing the area for advancement or spread 24 hours later.

Cheilosis. : Chapping and fissuring of the lips, which may be caused by vitamin B[sub]2 deficiency.

Chemical Debridement. : See under Debridement.

Clean. : Containing no foreign material or debris.

Clean Dressing. : Dressing that is not sterile but is free of environmental contaminants such as water damage, dust, pest and rodent contaminants, and gross soiling. See Chapter 5 for the specific measures necessary to keep dressings clean.

Clean Wound. : Wound free of purulent drainage, devitalized tissue, or dirt.

Colonized. : The presence of bacteria on the surface or in the tissue of a wound without indications of infection such as purulent exudate, foul odor, or surrounding inflammation. All Stage II, III, and IV pressure ulcers are colonized.

Contaminated. : Containing bacteria, other microorganisms, or foreign material. The term usually refers to bacterial contamination and in this context is synonymous with colonized. Wounds with bacterial counts of 10[sup]5 organisms per gram of tissue or less are generally considered contaminated; those with higher counts are generally considered infected.

Continuously Moist Saline Gauze. : See under Dressing.

Culture (Bacterial). : Removal of bacteria from a wound for the purpose of placing them in a growth medium in the laboratory to propagate to the point where they can be identified and tested for sensitivity to various antibiotics. Swab cultures are generally inadequate for this purpose.

Culture (Quantitative Bacterial). : Performing a bacterial culture in a manner that allows the number of bacteria present in a known quantity of tissue biopsy, wound aspirate, or sampled surface to be quantified.

Culture and Sensitivity. : Removal of bacteria from a wound for the purpose of placing them in a growth medium in the laboratory to propagate to the point where they can be identified and tested for sensitivity to various antibiotics.

Culture(Swab). : Technique involving the use of a swab to remove bacteria from a wound and place them in a growth medium for propagation and identification. Swab cultures obtained from the surface of a pressure ulcer are usually positive because of surface colonization and should not be used to diagnose ulcer infection.

Cytotoxic Cleansers. : Agents that can be used to cleanse wounds (to remove undesirable materials) but that have a specific destructive action on certain cells.

Dakin's® Solution. : Buffered sodium hypochlorite; a bactericidal wound irrigant.

Dead Space. : A cavity remaining in a wound.

Debridement. : Removal of devitalized tissue and foreign matter from a wound. Various methods can be used for this purpose:Autolytic Debridement. The use of synthetic dressings to cover a wound and allow eschar to self-digest by the action of enzymes present in wound fluids. Enzymatic (Chemical) Debridement. The topical application of proteolytic substances (enzymes) to breakdown devitalized tissue. Mechanical Debridement. Removal of foreign material and devitalized or contaminated tissue from a wound by physical forces rather than by chemical (enzymatic) or natural (autolytic) forces. Examples are wet-to-dry dressings, wound irrigation, whirlpool, and dextranomers. Sharp Debridement. Removal of foreign material or devitalized tissue by a sharp instrument such as a scalpel. Laser debridement is also considered a type of sharp debridement.

Decubitus Ulcer. : See Pressure Ulcer.

Dehiscence. : Separation of the layers of a surgical wound.

Delay of Flaps. : See under Operative Repair.

Deterioration. : Negative course. Failure of the pressure ulcer to heal, as shown by wound enlargement that is not brought about by debridement.

Dextranomers. : Highly hydrophilic dextran-polymer beads that are poured into secreting wounds to absorb wound exudates and act as a debriding agent.

Devitalized Tissue. : See Necrotic Tissue.

Direct Closure. : See under Operative Repair.

Disinfection. : A process that eliminates many or all pathogenic microorganisms on inanimate objects, with the exception of bacterial spores. Disinfection of pressure ulcers is neither desirable nor feasible.

Donut-Type Device. : See under Support Surfaces.

Dressing. : The material applied to a wound for the protection of the wound and absorbance of drainage. Alginate Dressing. A nonwoven absorptive dressing manufactured from seaweed. Film Dressing. A clear, adherent, nonabsorptive, polymer-based dressing that is permeable to oxygen and water vapor but not to water. Foam Dressing. A spongelike polymer dressing that may or may not be adherent; it may be impregnated or coated with other materials and has some absorptive properties. Gauze Dressing. A cotton or synthetic fabric dressing that is absorptive and permeable to water, water vapor, and oxygen. This dressing may be impregnated with petrolatum, antiseptics, or other agents. Wet-to-Dry Saline Gauze. A dressing technique in which gauze moistened with normal saline is applied wet to the wound and removed once the gauze becomes dry and adheres to the wound bed. The goal is to debride the wound as the dressing is removed. Continuously Moist Saline Gauze. A dressing technique in which gauze moistened with normal saline is applied to the wound and remoistened frequently enough so it will remain moist. The goal is to maintain a continuously moist wound environment. Hydrocolloid Dressing. An adhesive, moldable wafer made of a carbohydrate-based material, usually with a waterproof backing. This dressing usually is impermeable to oxygen, water, and water vapor and has some absorptive properties. Hydrogel Dressing. A water-based, nonadherent, polymer-based dressing that has some absorptive properties. Pastes/Powders/Beads. Agents formulated primarily to fill wound cavities that may have some absorptive properties.

Dynamic Device. : See under Support Surfaces.

Electrical Stimulation. : The use of an electrical current to transfer energy to a wound. The type of electricity that is transferred is controlled by the electrical source.

Endocarditis. : Inflammation of the innermost tunic of the heart, which includes the endothelium and subendothelial connective tissue.

Epithelialization. : The stage of tissue healing in which the epithelial cells migrate (move) across the surface of a wound. During this stage of healing, the epithelium appears the color of "ground glass" to pink.

Erythema. : Redness of the skin. Blanchable Erythema. Reddened area that temporarily turns white or pale when pressure is applied with a fingertip. Blanchable erythema over a pressure site is usually due to a normal reactive hyperemic response. Nonblanchable Erythema. Redness that persists when fingertip pressure is applied. Nonblanchable erythema over a pressure site is a symptom of a Stage I pressure ulcer.

Eschar. : Thick, leathery, necrotic, devitalized tissue.

Exudate. : Any fluid that has been extruded from a tissue or its capillaries, more specifically because of injury or inflammation. It is characteristically high in protein and white blood cells.

Fascia. : A sheet or band of fibrous tissue that lies deep below the skin or encloses muscles and various organs of the body.

Film Dressing. : See under Dressing.

Fluctuance. : Wavelike motion, indicative of the presence of fluid, used to describe the appearance of wound tissue.

Fluid Irrigation. : Cleansing by means of a stream of fluid, preferably saline.

Foam Dressing. : See under Dressing.

Foam Mattress Overlay. : See under Support Surfaces.

Free Flap. : See under Operative Repair.

Friction. : Mechanical force exerted when skin is dragged across a coarse surface such as bed linens.

Full Thickness Tissue Loss. : The absence of epidermis and dermis.

Gauze Dressing. : See under Dressing.

Glossitis. : Inflammation of the tongue, which may be due to multipleB-vitamin deficiencies.

Granulation Tissue. : The pink/red, moist tissue that contains new blood vessels, collagen, fibroblasts, and inflammatory cells, which fills an open, previously deep wound when it starts to heal.

Growth Factors. : Proteins that affect the proliferation, movement, maturation, and biosynthetic activity of cells. For the purposes of this guideline, these are proteins that can be produced by living cells.

Hand Check. : A method of checking whether a patient is "bottoming out." See Bottoming Out.

Handwashing. : Handwashing is the cornerstone of any infection-control program. Handwashing should be of sufficient duration to remove the transient microbial flora (10 seconds of soap and friction, followed by rinsing with running water).

Healing. : A dynamic process in which anatomical and functional integrity is restored. This process can be monitored and measured. For wounds of the skin, it involves repair of the dermis (granulation tissue formation) and epidermis (epithelialization). Healed wounds represent a spectrum of repair: They can be ideally healed (tissue regeneration), minimally healed (temporary return of anatomical continuity), or acceptably healed (sustained functional and anatomical result). The acceptably healed wound is the ultimate outcome of wound healing but not necessarily the appropriate outcome for all patients. Primary Intention Healing. Closure and healing of a sutured wound. Secondary Intention Healing. Closure and healing of a wound by the formation of granulation tissue and epithelialization.

Heterotopic Bone Formation. : Growth of bone at an abnormal site on the body. Such growth may be a complication of pressure ulcers.

Hydrocolloid Dressing. : See under Dressing.

Hydrogel Dressing. : See under Dressing.

Hydrotherapy. : Use of whirlpool or submersion in water for wound cleansing.

Hyperbaric Oxygen. : Oxygen at greater than atmospheric pressure that can be applied either to the whole patient inside a pressurized chamber or to a localized area (such as an arm or leg) inside a smaller chamber.

Hypoalbuminemia. : An abnormally low amount of albumin in the blood. A value less than 3.5 mg/dL is clinically significant. Albumin is the major serum protein that maintains plasma colloidal osmotic pressure (pressure within blood vessels) and transports fatty acids, bilirubin, and many drugs as well as certain hormones, such as cortisol and thyroxine, through the blood. Low serum albumin may be due to inadequate protein intake, active inflammation, or serious hepatic and renal disease and is associated with pressure ulcer development.

Incidence. : Rate at which new cases of a condition occur during a specific time period.

Infection. : The presence of bacteria or other microorganisms in sufficient quantity to damage tissue or impair healing. Clinical experience has indicated that wounds can be classified as infected when the wound tissue contains 10[sup]5 or greater microorganisms per gram of tissue. Clinical signs of infection may not be present, especially in the immunocompromised patient or the patient with a chronic wound.

Infection (Clinical). : The presence of bacteria or other microorganisms in sufficient quantity to overwhelm the tissue defenses and produce the inflammatory signs of infection--i.e., purulent exudate, odor, erythema, warmth, tenderness, edema, pain, fever, and elevated white cell count. Local Clinical Infection. A clinical infection that is confined to the wound and within a few millimeters of its margins. Systemic Clinical Infection. A clinical infection that extends beyond the margins of the wound. Some systemic infectious complications of pressure ulcers include cellulitis, advancing cellulitis, osteomyelitis, meningitis, endocarditis, septic arthritis, bacteremia, and sepsis. See Sepsis.

Inflammatory Response. : A localized protective response elicited by injury or destruction of tissues that serves to destroy, dilute, or wall off both the injurious agent and the injured tissue. Clinical signs include pain, heat, redness, swelling, and loss of function. Inflammation may be diminished or absent in immunosuppressed patients.

Innervation. : Nerve supply to an area of the body. Innervation is considered adequate if it is sufficient to sense temperature, touch, and pressure/pain and communicate this sensory information to the brain.

Interface Pressure. : See Pressure (Interface).

Irrigation. : Cleansing by a stream of fluid, preferably saline.

Ischemia. : Deficiency of blood supply to a tissue, often leading to tissue necrosis.

Local Clinical Infection. : See under Infection (Clinical).

Low-Air-Loss Bed. : See under Support Surfaces.

Macerate. : To soften by wetting or soaking. In this context it refers to degenerative changes and disintegration of skin when it has been kept too moist.

Malnutrition. : State of nutritional insufficiency due to either inadequate dietary intake or defective assimilation or utilization of food ingested. Clinically significant malnutrition is diagnosed if (1) serum albumin is less than 3.5 mg/dL, (2) the total lymphocyte count is less than 1,800/mm[sup]3, or (3) body weight has decreased more than 15 percent.

Mattress Replacement System. : See under Support Surfaces.

Mechanical Debridement. : See under Debridement.

Mechanical Loading. : The contribution of mechanical forces--i.e., pressure, friction, and shear--to the development of pressure ulcers.

Meningitis. : Inflammation of the membranes of the brain or spinal cord.

Moist Saline Gauze. : See under Dressing.

Moisture. : In the context of this document, moisture refers to skin moisture that may increase the risk of pressure ulcer development and impair healing of existing ulcers. Primary sources of skin moisture include perspiration, urine, feces, drainage from wounds, or fistulas.

Muscle Flap. : See under Operative Repair.

Musculocutaneous Flap. : See under Operative Repair.

Necrosis. : Death of tissue.

Necrotic Tissue. : Tissue that has died and has therefore lost its usual physical properties and biological activity. Also called "devitalized tissue."

Needle Aspiration. : Removal of fluid from a cavity by suction, often to obtain a sample (aspirate) for culturing.

Nonblanchable Erythema. : See under Erythema.

No-Touch Technique. : Method of changing surface dressings without touching the wound or the surface of any dressing that may be in contact with the wound. Adherent dressings should be grasped by the corner and removed slowly, whereas gauze dressings can be pinched in the center and lifted off.

Operative Repair. : In the context of this guideline, operative repair refers to a variety of surgical procedures designed to repair the pressure ulcer. Delay of Flaps. The development and transfer of a flap to a recipient site in more than one step to ensure its vascular supply. Direct Closure. Direct primary closure with sutures. This approach stretches the skin and creates tension that frequently leads to dehiscence and therefore is seldom used except for small, superficial ulcers. Free Flap. A procedure involving a muscle-type flap in which the vein and artery are disconnected at the donor site and reconnected to the vessels at the recipient site with the aid of a microscope. Muscle Flap. A procedure that moves a known muscle along with its vascular supply (either intact or reestablished) into a defect. Musculocutaneous Flap. A procedure that moves muscle combined with a portion of overlying skin having an intact vascular supply. The portion of skin overlying the muscle is fed by perforators within the muscle. This type of flap has several advantages: It is fed by named, identifiable blood vessels; supplies higher concentrations of oxygen to underlying bone, which may help heal osteomyelitis; can limit the effects of shear and ulcer recurrence; and provides more bulk, which may limit the effect of ischemia. However, muscle tolerates warm ischemia less well than skin. Sensate Flap. A procedure that moves muscle, skin, and a sensory nerve. The sensory nerve provides feeling to the flap. Skin Flap. A procedure that moves a section of skin and associated subcutaneous tissue from one part of the body to another, with the vascular supply maintained for nourishment. The vascular attachment can be the original vessel, rotated along with the flap; changed from one part of the flap to another; or reestablished by microvascular anastomoses once it has been placed in the new location. One disadvantage of local flap closure is that the flap essentially redistributes an already inadequately perfused tissue and is randomly dependent on an unpredictable local blood supply. Skin Graft. A procedure that moves a segment of dermis and a portion of epidermis. The graft is completely separated from its blood supply and donor site and moved to a recipient site. Skin grafts contain varying portions of epidermis and dermis and can be full thickness or partial thickness, depending upon how much dermis is included in the graft. One disadvantage of skin grafts applied to granulating bone is that there is no padding and they quickly erode. Tissue Expansion. A surgical technique during which an expandable device is placed beneath viable skin. The device is expanded with serial injections of saline and when the skin has stretched, it is moved to cover a nearby defect. V-Y Advancement. This procedure derives its name from the appearance of the postoperative wound. After an incision is made in the shape of a "V," the apex of the "V" is closed by advancing the central portion. This leaves a scar that looks like a "Y."

Osteomyelitis. : Inflammation of the bone marrow and adjacent bone, often due to infection.

Overlay. : See under Support Surfaces.

Pastes/Powders/Beads. : See under Dressing.

Perineal-Urethral Fistula.: An abnormal passageway between the perineum (area between the scrotum or vulva and the anus) and the urethra (canal conveying urine from the bladder to the exterior of the body). Such a fistula may be a complication of pressure ulcer(s).

Phagocytic Demand. : The amount of particulate material (such as bacteria) that white blood cells must ingest in an area.

Phagocytosis. : The process of ingestion and digestion of bacteria, cells, necrotic tissue, or debris by white blood cells in an injured area.

Polypharmacy. : The administration of many drugs concurrently, usually meaning that a patient is receiving an excessive number of medications. Polypharmacy may negatively affect adherence to the pressure ulcer treatment plan.

Pressure (Interface). : Force per unit area that acts perpendicularly between the body and the support surface. This parameter is affected by the stiffness of the support surface, the composition of the body tissue, and the geometry of the body being supported.

Pressure Reduction. : Reduction of interface pressure, not necessarily below the level required to close capillaries (i.e., capillary-closing pressure).

Pressure Relief. : Reduction of interface pressure below capillary-closing pressure.

Pressure Ulcer. : Any lesion caused by unrelieved pressure resulting in damage of underlying tissue. Also called decubitus ulcer, pressure sore, and bed sore. Pressure ulcers are usually located over bony prominences and are graded or staged to classify the degree of tissue damage observed. Such staging is used as a tool for communication and assessment. The recommendations regarding staging put forth by this panel are consistent with those of the National Pressure Ulcer Advisory Panel Consensus Development Conference (NPUAP, 1989), as derived from previous staging systems proposed by Shea (1975) and the Wound Ostomy and Continence Nurses Society (WOCN). Numerical identification of stages does not necessarily imply a progression in ulcer severity. For example, a Stage I ulcer may have very little tissue damage or it may have necrotic underlying tissue, because muscle tissue is more sensitive than skin to pressure-induced ischemia. Pressure ulcers are staged as follows: Stage I. Nonblanchable erythema of intact skin, the heralding lesion of skin ulceration. In individuals with darker skin, discoloration of the skin, warmth, edema, induration, or hardness may also be indicators. Stage II. Partial thickness skin loss involving epidermis, dermis, or both. The ulcer is superficial and presents clinically as an abrasion, blister, or shallow crater. Stage III. Full thickness skin loss involving damage to or necrosis of subcutaneous tissue that may extend down to, but not through, underlying fascia. The ulcer presents clinically as a deep crater with or without undermining of adjacent tissue. Stage IV. Full thickness skin loss with extensive destruction, tissue necrosis, or damage to muscle, bone, or supporting structures (e.g., tendon, joint capsule). Undermining and sinus tracts may also be associated with Stage IV pressure ulcers. The following limitations are inherent in these definitions: Because the skin remains intact in Stage I pressure ulcers, these lesions are not ulcers in the usual sense. In addition, Stage I pressure ulcers are not always reliably assessed, especially in patients with darkly pigmented skin. A reliable system to accurately identify Stage I pressure ulcers in individuals with darkly pigmented skin should be developed. Despite these limitations, identification of a Stage I pressure ulcer is critical for indicating the need for more vigilant assessment and preventive care. When eschar is present, a pressure ulcer cannot be accurately staged until the eschar has been removed. It may be difficult to assess pressure ulcers in patients with casts, other orthopedic devices, or support stockings. Routine assessment to check for adequate circulation, movement, and sensation may fail to detect pressure ulcers beneath casts. Health care providers should (1) assess the skin under the edges of casts, (2) be alert to patient complaints of pres- sure-induced pain, (3) determine whether casts need to be altered or replaced to relieve pressure, and (4) remove support stockings to assess the skin.

Prevalence. : The number of cases present in a population at one point in time.

Primary Intention Healing. : See under Healing.

Pseudoaneurysm. : Dilatation and tortuosity of a blood vessel, a potential complication of pressure ulcers.

psi. : Pounds per square inch--a unit of pressure, in this case, the pressure exerted by a stream of fluid against one square inch of skin or wound surface.

Purulent Discharge/Drainage. : A product of inflammation that contains pus--i.e., cells (leukocytes, bacteria) and liquefied necrotic debris.

Qualitative Data. : Information that describes the nature or qualities of a subject.

Quantitative Bacterial Culture. : See Culture.

Quantitative Data. : Information that describes the characteristics of a subject in numerical or quantitative terms.

Reactive Hyperemia. : Reddening of the skin caused by blood rushing back into ischemic tissue.

Repositioning. : Any change in body position that relieves pressure from tissue overlying bony prominences. Periodic repositioning of chairbound and bedfast individuals is one of the most basic and frequently used methods of reducing pressure. The overall goal of repositioning is to allow tissue reperfusion and thus prevent ischemic tissue changes. The term "repositioning" implies a sustained relief of pressure, not just a temporary shift. Specific repositioning techniques and the frequency of repositioning should be individualized according to the patient's level of risk and the goals of care.

Saline Gauze. : See under Dressing.

Secondary Intention Healing. : See under Healing.

Sensate Flap. : See under Operative Repair.

Sepsis. : The presence of various pus-forming and other pathogenic organisms or their toxins, in the blood or tissues. Clinical signs of blood-borne sepsis include fever, tachycardia, hypotension, leukocytosis, and a deterioration in mental status. The same organism is often isolated in both the blood and the pressure ulcer.

Septic Arthritis. : Inflammation of joints caused by bacterial invasion, a potential complication of pressure ulcers.

Seroma. : A collection of serum/plasma within a wound.

Sharp Debridement. : See under Debridement.

Shear. : Mechanical force that acts on a unit area of skin in a direction parallel to the body's surface. Shear is affected by the amount of pressure exerted, the coefficient of friction between the materials contacting each other, and the extent to which the body makes contact with the support surface.

Sinus Tract. : A cavity or channel underlying a wound that involves an area larger than the visible surface of the wound.

Skin Equivalent. : A material used to cover open tissue that acts as a substitute for nascent (beginning) dermis and epidermis and that has at least some of the characteristics of human skin (e.g., amniotic tissue, xenografts, human allografts). For the purpose of this guideline, only tissue with viable, biologically active cells is given this designation.

Skin Flap. : See under Operative Repair.

Skin Graft.: See under Operative Repair.

Slough. : Necrotic (dead) tissue in the process of separating from viable portions of the body.

Squamous Cell Carcinoma. : A malignant new growth that arises from epithelial cells and has a cuboid appearance. When arising within a chronic ulcer, it is commonly referred to as Marjolin's ulcer.

Stasis Ulcer. : Ulceration associated with ambulatory venous hypertension.

Static Air Mattress. : See under Support Surfaces.

Static Device. : See under Support Surfaces.

Static Support Surface. : See under Support Surfaces.

Static Water Mattress. : See under Support Surfaces.

Stratum Corneum. : Outermost layer of the epidermis.

Support Surfaces. : Special beds, mattresses, mattress overlays, or seat cushions that reduce or relieve pressure while sitting or lying. Air-Flotation Bed. Generic descriptor for low-air-loss beds and air-fluidized beds. Air-Fluidized Bed. Class of support surfaces that uses a high rate of air flow to fluidize fine particulate material (such as sand) to produce a support medium that has characteristics similar to a liquid. Alternating-Air Mattress or Overlay. Mattress or overlay with interconnecting air cells that cyclically inflate and deflate to produce alternating high and low pressure intervals. Cells with larger depth and diameter produce greater pressure relief over the body. Donut-Type Device. A rigid, ring-shaped device created to relieve pressure on the sitting surface. This device is not recommended, because even though pressure is relieved in the tissue over the center of the ring, pressure in tissue resting on the ring causes vascular congestion and may impede circulation to the tissues. Dynamic Device (or Dynamic Support Surface). Pressure-reducing device designed to change its support characteristics in a cyclical fashion. Examples include alternating-air mattresses and mechanical seats that change shape and redistribute pressure. Foam Mattress Overlay. Thick foam slab with a textured surface designed to be placed on top of the standard hospital mattress to reduce pressure by enveloping the body. Its effectiveness is influenced by its thickness, density, and stiffness. Low-Air-Loss Bed. A series of interconnected woven fabric air pillows that allow some air to escape through the support surface. The pillows can be variably inflated to adjust the level of pressure relief. Mattress Replacement System. Mattress with pressure-reducing or pressure-relieving features that can be placed on an existing bed frame. Overlay. General term used to describe support surfaces placed on top of a standard hospital mattress. Static Air Mattress. A vinyl mattress overlay composed of interconnected air cells that are inflated with a blower before use. The shifting of air among the cells distributes pressure uniformly over the support area to create a flotation effect. Static Device (or Static Support Surface). Pressure-reducing device designed to provide support characteristics that remain constant--i.e., do not cycle in time. Examples include foam overlays, cushions, and water mattresses. Static Water Mattress. A vinyl mattress or overlay composed of interconnected compartments that are filled with water to distribute pressure uniformly over the support surface to create a flotation effect.

Surfactants. : A surface-active agent that reduces the surface tension of fluids to allow greater penetration.

Swab Culture. : See Culture (Swab).

Systemic Clinical Infection. : See under Infection (Clinical).

Tissue Biopsy. : Use of a sharp instrument to obtain a sample of skin, muscle, or bone.

Tissue Expansion. : See under Operative Repair.

Tissue Load. : The distribution of pressure, friction, and shear on tissue.

Topical Antibiotic. : A drug known to inhibit or kill microorganisms that can be applied locally to a tissue surface.

Topical Antiseptic. : Product with antimicrobial activity designed for use on skin or other superficial tissues; may damage some cells.

Trochanter. : Bony prominence on the upper part of the femur.

Tunneling. : A passageway under the surface of the skin that is generally open at the skin level; however, most of the tunneling is not visible.

Underlying Tissue. : Tissue that lies beneath the surface of the skin such as fatty tissue, supporting structures, muscle, and bone.

Undermining. : A closed passageway under the surface of the skin that is open only at the skin surface. Generally it appears as an area of skin ulceration at the margins of the ulcer with skin overlying the area. Undermining often develops from shearing forces.

V-Y Advancement. : See under Operative Repair.

Wet-to-Dry Saline Gauze. : See under Dressing.

Wound Healing. : See Healing.