# Acronyms

AHCPR : Agency for Health Care Policy and Research

APIC : Association for Practitioners in Infection Control

bFGF : Basic fibroblast growth factor

BMI : Body mass index

BSI : Body substance isolation

CDC : Centers for Disease Control and Prevention

CT : Computerized tomography

CURN : Conduct and Utilization of Research in Nursing

DHHS : U.S. Department of Health and Human Services

DMERC : Durable Medical Equipment Regional Carrier

FDA : Food and Drug Administration

IAET : International Association for Enterostomal Therapy

LD : Indentation load deflection

MRI : Magnetic resonance imaging

MRSA : Methicillin-resistant Staphylococcus aureus

NLM : National Library of Medicine

NPC : Nonprotein calories

NPUAP : National Pressure Ulcer Advisory Panel

OBRA : Omnibus Budget Reconciliation Act

OSHA : Occupational Safety and Health Administration

PHS : Public Health Service

psi : pounds per square inch

QI : Quality Improvement

RDA : Recommended daily allowance

rPDGF-BB : Recombinant platelet-derived growth factor-BB

TFL : Tensor fascia lata

TLC : Total lymphocyte count

TPN : Total parenteral nutrition

WBC : White blood count

WOCN : Wound Ostomy and Continence Nurses Society (formerly IAET)